# La depresión después de una lesión cerebral

Guía para pacientes y personas que ayudan con el cuidado

## ¿Es esta guía apropiada para mí?

### Es apropiada si

- Sufrió una lesión cerebral leve, moderada o grave, a causa de un golpe repentino. Esta guía es para usted aunque no lo haya atendido un médico cuando sufrió la lesión.
- Un médico u otro profesional de atención médica le ha dicho que usted sufrió una lesión en el cerebro.
- Esta guía es para usted, aun cuando no se haya sentido deprimido después de la lesión cerebral.

### ¿De dónde proviene la información de esta guía?

La información de esta guía proviene de la revisión de muchos estudios sobre la relación que existe entre los golpes en el cerebro y la depresión. La revisión fue realizada por un centro de investigación independiente y financiada por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ por su sigla en inglés), organismo de investigación del gobierno de Estados Unidos. El informe completo puede leerse en www.effectivehealthcare.ahrq.gov/tbidep.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es traumatismo cerebral?

“Traumatismo cerebral” (TBI, por su sigla en inglés) es el nombre médico de un daño causado al cerebro por una fuerza determinada, como puede ser:

- Un golpe directo en la cabeza causado por un objeto.
- Una caída en el suelo o en una superficie dura.
- Un choque en un automóvil, motocicleta o bicicleta.
- Una explosión o estallido muy cerca de la cabeza.

Para determinar si su lesión es leve, moderada o grave, los médicos pueden basarse en lo que sucedió al momento de la lesión (si perdió usted la conciencia, si no podía ver bien o si perdió algo de memoria), además de otros exámenes. En los Estados Unidos, cerca de 1.5 millones de personas (que no prestan servicio militar) sufren algún tipo de TBI cada año. También es probable que la cifra pueda ser mayor, si se considera que muchas personas con TBI leve no acuden a la sala de emergencia ni reportan su lesión. La mayoría de los casos de TBI (75 por ciento) son leves.

### Problemas que causa el traumatismo cerebral

Cualquier lesión cerebral—por leve que sea—puede causar problemas como dolor de cabeza, zumbido de oídos, cambios en el estado de ánimo o dificultad para recordar o pensar mucho tiempo. Tal vez descubra que han cambiado sus hábitos de sueño o se sienta cansado con mayor frecuencia.

Incluso varios meses o años después de su lesión cerebral puede usted notar otros problemas, como depresión o ansiedad.

## Relación entre la depresión y el traumatismo cerebral

### ¿Qué es la depresión?

La depresión es algo más que sentirse triste de vez en cuando. Es normal que la persona que sufre un traumatismo cerebral (TBI) se sienta triste por los problemas originados por la lesión. Pero en algunas personas, esos sentimientos pueden ir más allá de la sensación normal de tristeza. La persona que tiene depresión siente, casi todos los días, tristeza, falta de energía, cansancio o le es imposible disfrutar de eventos cotidianos. Otros síntomas son: dificultad para dormir, pérdida del apetito, problemas para prestar atención o concentrarse, sentimientos de culpa o inutilidad, o pensamientos sobre suicidio.

La depresión es un problema serio, pero tratable, que no debe desatenderse. Para aliviar su depresión, muchas personas necesitan algún tipo de tratamiento recetado por el médico u otro profesional de atención médica.

### ¿Qué tan frecuente es la depresión en las personas con traumatismo cerebral?

La investigación indica que la depresión es más común en las personas que han tenido traumatismo cerebral (TBI) que en las que no han sufrido este tipo de lesión.

De cada 10 personas que NO han tenido una lesión cerebral, aproximadamente una de ellas tendrá depresión.

De cada 10 personas que SÍ han sufrido una lesión cerebral, aproximadamente tres tendrán depresión.

### ¿Qué factores aumentan mi riesgo de tener depresión?

El TBI aumenta el riesgo de tener depresión, independientemente de que la lesión sea leve, moderada o grave. Los investigadores no saben aún si la edad, el género, la parte afectada del cerebro o el tipo de lesión, aumentan la posibilidad de tener depresión.

### ¿Cuánto tiempo después de la lesión puede darme depresíon?

Los investigadores no saben cuándo es más probable que ocurra la depresión después de un TBI. Algunas personas experimentan depresión poco después de la lesión, mientras que otras la desarrollan después de un año o más. Es importante que informe a su médico cualquier síntoma de depresión que pueda tener, aun cuando haya pasado un tiempo desde que tuvo su lesión cerebral. Su médico u otro profesional de atención médica le harán una serie de preguntas o le pedirán responder un cuestionario o formulario para saber si tiene depresión.

### ¿Cómo puedo saber si tengo depresión?

Hay varios signos que le ayudarán a saber si tiene usted depresión.

- El sentirse desanimado, deprimido o triste la mayor parte del día.
- Cambios en sus hábitos de sueño, como falta de sueño o dormir más de lo habitual.
- Pérdida del interés en las actividades comunes, como pasatiempos favoritos, la convivencia con la familia o actividades con los amigos.
- Aumento del consumo de bebidas alcohólicas, drogas o tabaco.
- Comer menos o más que antes, independientemente de que tenga o no hambre.
- Sentimientos profundos de tristeza, desesperación o desesperanza.
- Pensamientos sobre suicidio.

Es posible que usted no advierta algunos de estos síntomas, pero que sí los noten otras personas que viven y trabajan cerca de usted. Es aconsejable preguntarle a esa gente cercana si ha notado en usted estos signos.

### ¿Qué debo hacer si estos síntomas empiezan a aparecer?

Avise a su médico o profesional de atención médica tan pronto como usted o las personas cercanas noten algún síntoma.

Si ha pensado en el suicidio, solicite ayuda al National Suicide Prevention Lifeline (Red Nacional de Prevención del Suicidio), llamando al 1-888-628-9454 (en español), o visite http://www.suicidepreventionlifeline.org/Culture/es/Default.aspx.

## Conozca sus opciones

### ¿Cómo se trata la depresión?

La depresión suele tratarse de dos maneras:

- Con orientación personal por parte de un profesional de atención médica especializado. Es lo que se llama “psicoterapia”.
  ▲ En la psicoterapia, usted y un profesional de atención médica capacitado hablan de sus síntomas y buscan formas de resolverlos.
  ▲ Tal vez deba reunirse con el terapeuta cada semana por varios meses o más, dependiendo de cómo se sienta.
- Con medicamentos llamados “antidepresivos”.
  ▲ Se utilizan varios tipos de antidepresivos para tratar la depresión y la ansiedad.
  ▲ Es posible que necesite tomar estos medicamentos durante algunos meses o más, dependiendo de cómo se sienta.

En muchos casos, la persona necesita tanto psicoterapia como medicamentos.

Los investigadores desconocen los beneficios y daños o efectos secundarios específicos de la psicoterapia y los antidepresivos en las personas con TBI. Sin embargo, tanto la psicoterapia como los antidepresivos han ayudado a las personas con depresión.

### ¿Causan efectos secundarios los antidepresivos?

Todos los antidepresivos pueden causar efectos secundarios.

Los investigadores desconocen si los efectos secundarios son diferentes entre las personas que tienen TBI y las otras que toman antidepresivos. Sin embargo, la investigación ha demostrado que en algunas personas los antidepresivos pueden causar:

- Dolor estomacal o intestinal y diarrea.
- Aumento o pérdida de peso.
- Náusea y vómito.
- Problemas sexuales.
- Dificultad para dormir o sentirse con sueño durante el día.

Hable con médico sobre los posibles efectos secundarios que causan los medicamentos antidepresivos.

Es de preocupación especial para las personas que sufren de TBI, entender cómo los antidepresivos pueden afectar a otros medicamentos que se toman para el traumatismo cerebral. Es importante que informe su médico o profesional de atención médica sobre los otros medicamentos que toma..

## Su médico podrá ayudarle a decidir

### Informe a su médico

Es importante que se ponga en contacto con su médico si experimenta:

1. Cambios en los hábitos de sueño o alimentación.
2. Sensación frecuente de tristeza, desesperanza, ansiedad o pánico.
3. Desinterés en sus actividades favoritas.
4. Pensamientos sobre suicidio.

### Pregunte a su médico

Si va a recibir tratamiento para la depresión o ansiedad, después de una lesión cerebral, tal vez quiera hacerle las siguientes preguntas a su médico:

1. ¿Con qué frecuencia debo examinarme para saber si estoy desarrollando depresión o un problema de ansiedad?
2. ¿Cuanto tiempo cree que necesitaré psicoterapia o medicamentos para tratar estos problemas?

Otras preguntas que puede hacerle a su médico:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuentes

La información de esta guía proviene del informe Traumatic Brain Injury and Depression (Lesion cerebral traumática y depresión). Fue producida por la Vanderbilt University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Vanderbilt), con el financiamiento de la Agency for Healthcare Research and Quality (AHRQ) (Agencia para la Investigacíon y la Calidad de la Atencíon Médica, por su sigla en inglés). La información sobre los efectos secundarios de los antidepresivos proviene del informe Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Depression (Comparación de la efectividad de los antidepresivos de segunda generación en el tratamiento farmacológico de la depresión). Fue producida por el RTI International-University of North Carolina Evidence-based Practice Center (RTI Internacional del Centro de Práctica Basada en la Evidencia de la Universidad de Carolina del Norte), con el financiamiento de la AHRQ. Para obtener una copia de esos informes o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite http://www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol/. Se obtuvo información adicional para esta guía de la página web de Medline-Plus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/traumaticbraininjury.html.

Esta guía abreviada fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science en el Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas en la Facultad de Medicina de Baylor) de Houston, TX.