# Trasplantes de médula ósea o de células madre sanguíneas en niños con ciertas enfermedades metabólicas hereditarias y raras^*^

Revisión de la investigación para padres y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Esta información es para usted si

- El médico del niño ha dicho que tiene una de estas “enfermedades metabólicas hereditarias” raras:
  - Enfermedad de Wolman
  - Enfermedad de Farber tipo 2 ó 3
  - Enfermedad de Niemann-Pick tipo A
  - Enfermedad de Gaucher tipo 3
  - Lipofuscinosis ceroide neuronal infantil temprana (NCL, por su sigla en inglés)
  - Síndrome de Hunter (mucopolisacaridosis tipo 2)
  - Síndrome de Sanfilippo (mucopolisacaridosis tipo 3)
- El médico del niño le ha hablado de un trasplante de células madre hematopoyéticas (HSCT, por su sigla en inglés) en el que se usan células madre de un donante. Puede llamarse también trasplante de células madre sanguíneas o trasplante de médula ósea.
- Su hijo tiene menos de 21 años de edad. La información de este resumen proviene de investigaciones en niños menores de 21 años.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Información sobre cada enfermedad metabólica hereditaria rara
- Beneficios posibles de un HSCT
- Lo que han encontrado los investigadores sobre el tratamiento de estas enfermedades en niños mediante un HSCT en el que se usan células madre de un donante
- Qué es un HSCT y cómo se realiza
- Riesgos posibles de un HSCT

Este resumen puede ayudarle a hablar con el médico para saber si un HSCT podría ayudar a su niño.

Nota: El HSCT puede no ser útil en todos los niños con una de estas enfermedades. Vea en la página 8 y 9 lo que los investigadores han encontrado sobre el tratamiento de cada enfermedad mediante un HSCT en el que se usan células madre de un donante.

### ¿De dónde proviene la información?

Los investigadores revisaron estudios acerca de los HSCT en niños con diferentes enfermedades. Esos estudios se publicaron entre enero de 1995 y agosto de 2011. Los investigadores fueron financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal.

Los investigadores escribieron un informe sobre lo que encontraron y este resumen se basa en ese informe. El informe fue revisado por médicos, investigadores, otros expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/stem-cell-children.cfm (disponible sólo en inglés).

## Conozca la condición de su hijo

### ¿Qué son las enfermedades metabólicas hereditarias raras y cómo puede ayudar un HSCT?

La enfermedad de Wolman, la enfermedad de Farber, la enfermedad de Niemann-Pick, la enfermedad de Gaucher, la NCL infantil temprana, el síndrome de Hunter y el síndrome de Sanfilippo pertenecen al grupo de las “enfermedades metabólicas hereditarias”. Son enfermedades raras causadas por cierto gen que no funciona correctamente. Estas enfermedades no son causadas por nada que la madre haya hecho durante el embarazo.

Las enfermedades metabólicas hereditarias se pueden transmitir dentro de una familia aun cuando ambos padres estén sanos. El niño obtiene dos copias del gen de sus padres. Para que el niño sea sano, basta con que una copia del gen funcione correctamente. Pero cuando recibe dos genes que no funcionan (uno de la madre y uno del padre), el niño puede desarrollar una enfermedad metabólica.

En casos raros, un niño puede recibir un gen que funciona y otro que no, y el gen que funciona puede dañarse por sí solo. Esto puede hacer que el niño desarrolle una enfermedad metabólica.

En los niños con enfermedad de Wolman, enfermedad de Farber, enfermedad de Niemann-Pick, enfermedad de Gaucher o NCL infantil temprana:

- El cuerpo no produce la cantidad suficiente de una sustancia (llamada enzima) que es necesaria para desintegrar o procesar las moléculas de grasa.
- Puesto que el cuerpo no puede desintegrar correctamente las moléculas de grasa, una cantidad dañina de estas moléculas se acumula en el cuerpo y daña los órganos.

En niños con síndrome de Hunter o síndrome de Sanfilippo:

- El cuerpo no produce la cantidad suficiente de una sustancia (llamada enzima) que es necesaria para desintegrar o procesar las moléculas de azúcar.
- Puesto que el cuerpo no puede desintegrar correctamente las moléculas de azúcar, una cantidad dañina de estas moléculas se acumula en el cuerpo y daña los órganos.

En un HSCT para tratar las enfermedades metabólicas hereditarias raras, se introducen en el cuerpo del niño células madre sanas de un donante (persona que dona células madre). De las células madre, se desarrollan células sanguíneas sanas. El objetivo buscado es que estas nuevas células sanguíneas proporcionen la enzima faltante que el cuerpo del niño necesita.

En los niños con enfermedades metabólicas hereditarias raras que pueden dañar el cerebro y la médula espinal, cabe esperar que el HSCT impida ese daño si se hace lo suficientemente temprano. Un HSCT no puede revertir el daño que ya haya ocurrido.

En las páginas siguientes, se ofrece una breve descripción de las enfermedades metabólicas hereditarias raras que cubre este resumen.

#### Enfermedad de Wolman

La enfermedad de Wolman se manifiesta en las primeras semanas después del nacimiento. Causa la acumulación de cantidades dañinas de moléculas de grasa en el hígado, el bazo, la médula ósea, el intestino delgado y en las glándulas situadas encima de los riñones. Los niños con enfermedad de Wolman no pueden absorber los nutrientes, lo que causa desnutrición grave. A menudo, los niños con esta enfermedad no viven más de 6 meses a 1 año.

Los síntomas pueden incluir
- Falta de crecimiento, de aumento de peso o de un desarrollo normal
- Ictericia (tono amarillento de la piel y la parte blanca de los ojos)
- Bajo número de glóbulos rojos (las células que llevan el oxígeno a todo el cuerpo)
- Vómito grave
- Diarrea
- Hinchazón del abdomen
- Hinchazón del hígado y el bazo

#### Enfermedad de Farber de tipos 2 y 3

Los tipos 2 y 3 de la enfermedad de Farber aparecen en las primeras semanas posteriores al nacimiento. Esta enfermedad causa la acumulación de cantidades dañinas de moléculas de grasa en el cuerpo, especialmente en las articulaciones. Las moléculas de grasa pueden acumularse también en el cerebro y la médula espinal. Los tipos 2 y 3 son las formas más leves de la enfermedad de Farber. Los niños con una de estas formas pueden vivir hasta la adolescencia.

Los síntomas pueden incluir
- Bolitas de grasa (nódulos) debajo de la piel, en los pulmones o en otras partes del cuerpo
- Articulaciones hinchadas y dolorosas
- Dificultad para respirar y/o para tragar
- Vómito
- Llanto débil
- Ronquera
- Hinchazón del hígado y el bazo
- Discapacidad mental

#### Enfermedad de Niemann-Pick tipo A

La enfermedad de Niemann-Pick tipo A aparece en los primeros meses posteriores al nacimiento. Causa la acumulación de cantidades dañinas de moléculas de grasa en el hígado, el bazo, los pulmones, la médula ósea y el cerebro. El tipo A es la forma más grave de la enfermedad de Niemann-Pick y los niños con esta enfermedad a menudo no viven más de 3 años.

Los síntomas pueden incluir
- Debilidad muscular
- Sensibilidad al tacto
- Dificultad para tragar
- Arrastrar o no articular bien las palabras
- Dificultad para aprender
- Incapacidad para mover los ojos hacia arriba y abajo
- Discapacidad mental
- Hinchazón del hígado y el bazo

#### Enfermedad de Gaucher tipo 3

La enfermedad de Gaucher tipo 3 puede aparecer en cualquier momento durante la niñez o la adolescencia. Causa la acumulación de cantidades dañinas de moléculas de grasa en el hígado, el bazo, los pulmones, la médula ósea y el cerebro. Los niños con el tipo 3 de la enfermedad de Gaucher pueden vivir hasta la edad adulta.

Los síntomas pueden incluir
- Dolor y fracturas en los huesos
- Fácil formación de moretones
- Bajo número de glóbulos rojos (las células que llevan el oxígeno a todo el cuerpo)
- Hinchazón del hígado y el bazo
- Problemas de los ojos
- Convulsiones
- Discapacidad mental
- Problemas pulmonares

#### Lipofuscinosis ceroide neuronal infantil temprana

La NCL infantil temprana aparece en el primer año de vida. Causa la acumulación de cantidades dañinas de moléculas de grasa en las células, por lo común en el cerebro o los ojos del niño y a veces en la piel, los músculos y otros tejidos. Los niños con esta enfermedad a menudo no viven más allá de los 6 a 13 años.

Los síntomas pueden incluir
- Pérdida de la vista que culmina en ceguera
- Convulsiones
- Problemas para dormir
- Dificultad para hablar
- Problemas de conducta
- Problemas del movimiento y dificultad para caminar
- Discapacidad mental

#### Síndrome de Hunter

El síndrome de Hunter aparece en los niños desde los 18 meses y afecta principalmente a los varones. Causa la acumulación de cantidades dañinas de moléculas de azúcar en las células, la sangre y los tejidos que están entre los órganos y los huesos en el niño. El síndrome de Hunter tiene una forma grave y una leve. La forma grave suele comenzar en la niñez temprana (incluso desde los 18 meses) y causa discapacidad mental. A menudo, los niños con síndrome de Hunter grave viven de 10 a 20 años. La forma leve suele comenzar más tarde en la niñez o en la adolescencia. Los niños con síndrome de Hunter leve suelen vivir de 20 a 60 años.

Los síntomas pueden incluir
- Cabeza grande
- Problemas del oído, la vista o ambos
- Articulaciones rígidas
- Rigidez muscular
- Conducta agresiva
- Rasgos faciales toscos, especialmente los labios y la nariz
- Síndrome del túnel carpiano (entumecimiento o debilidad en las manos y los dedos)
- Órganos agrandados
- Dificultad para respirar, por engrosamiento de los conductos nasales y la tráquea
- Retraso del desarrollo y el crecimiento

#### Síndrome de Sanfilippo

El síndrome de Sanfilippo aparece después del primer año de vida del niño. Causa la acumulación de cantidades dañinas de moléculas de azúcar en las células, principalmente en el cerebro y la médula espinal del niño. A menudo, los niños con esta enfermedad viven solamente hasta la adolescencia.

Los síntomas pueden incluir
- Cabeza grande
- Rasgos faciales toscos, especialmente los labios y las cejas
- Articulaciones rígidas
- Problemas para caminar
- Diarrea
- Problemas de conducta
- Retraso del desarrollo
- Discapacidad mental grave

### ¿Qué han encontrado los investigadores acerca del tratamiento mediante HSCT en los niños que tienen una enfermedad metabólica hereditaria rara?

El diagrama siguiente muestra lo que los investigadores encontraron sobre el uso de HSCT para tratar a niños con una enfermedad metabólica hereditaria rara.

Nota: Es importante advertir que los resultados de las investigaciones referentes a cada enfermedad se basan en un número muy pequeño de estudios, con muy pocos niños. Pregunte al médico de su hijo si estos resultados de investigación son aplicables a su caso y si un HSCT podría ayudarle a su hijo.

Enfermedad metabólica hereditaria rara | Los investigadores descubrieron que un HSCT: | N^o^ de pacientes estudiados en las investigaciones
Enfermedad de Wolman | - Aumentó la probabilidad de sobrevivir en comparación con simplemente tratar los síntomas para ayudar a aumentar la comodidad del niño | 7 pacientes
Enfermedad de Farber tipo 2 ó 3 | - Redujo la cantidad de nódulos bajo la piel más que el tratamiento usual; - Redujo la cantidad de articulaciones hinchadas más que el tratamiento usual^*^ | 5 pacientes
Enfermedad de Niemann- Pick tipo A | - Al parecer, no aumentó la posibilidad de sobrevivir en comparación con simplemente tratar los síntomas para aumentar la comodidad del niño | 3 pacientes
Enfermedad de Gaucher tipo 3 | - Al parecer, no mejoró el desarrollo mental^**^ más que la terapia de reemplazo enzimático^‡^, pero se necesita más investigación para saberlo con certeza. | 18 pacientes
NCL infantil temprana | - Al parecer, no mejoró el desarrollo mental^**^ en comparación con simplemente tratar los síntomas para aumentar la comodidad del niño | 3 pacientes
Síndrome de Hunter leve | - Puede mejorar el desarrollo mental^**^ y físico^†^ más que la terapia de reemplazo enzimático^‡^, pero se necesita más investigación para saberlo con certeza | 6 pacientes
Síndrome de Hunter grave | - Puede mejorar el desarrollo físico^†^ más que la terapia de reemplazo enzimático^‡^, pero se necesita más investigación para saberlo con certeza; - Al parecer, no mejoró el desarrollo mental^**^ más que la terapia de reemplazo enzimático^‡^, pero se necesita más investigación para saberlo con certeza. | 8 pacientes
Síndrome de Sanfilippo | - Al parecer, no mejoró el desarrollo mental^**^ o físico^†^ más que el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza | 9 pacientes

* El tratamiento usual difiere según la enfermedad. Pregunte al médico del niño cuál es el tratamiento usual para la enfermedad de su hijo.

** El desarrollo mental incluye el coeficiente intelectual, las destrezas de interacción social las destrezas del habla y el lenguaje, la capacidad para concentrarse y el desempeño escolar.

† El desarrollo físico incluye la capacidad de crecer normalmente, la capacidad de moverse y caminar, la flexibilidad de las articulaciones y el desarrollo de los huesos.

‡ La terapia de reemplazo enzimático es un tratamiento en el que se administra una forma artificial de la enzima que le falta a su niño, por medio de un tubo intravenoso (IV) colocado en el brazo.

## Aprenda sobre el trasplante de células madre hematopoyéticas

### ¿Qué son las células madre hematopoyéticas?

Las células madre hematopoyéticas son células jóvenes que al desarrollarse se convierten en sanguíneas. Existen tres tipos de células sanguíneas:

- Los glóbulos rojos transportan el oxígeno a todo el cuerpo.
- Los glóbulos blancos son parte importante del sistema inmunológico, que protege al cuerpo contra los microbios.
- Las plaquetas ayudan a la sangre a coagular.

Las células madre se encuentran principalmente en la médula ósea (el tejido esponjoso de los huesos). En la médula ósea, las células madre se multiplican y se desarrollan hasta convertirse en células sanguíneas. Cuando las células sanguíneas completan su desarrollo, entran en el torrente sanguíneo. Algunas células madre pueden encontrarse también en el torrente sanguíneo.

Nota: Las células madre hematopoyéticas no son células madre tomadas de un embrión (un óvulo humano fecundado por espermatozoides) y no son lo mismo que las células madre que se utilizan en la clonación.

### ¿Cuál es el proceso para obtener un HSCT?

Un HSCT para tratar enfermedades metabólicas hereditarias raras consiste en introducir células madre sanas de un donante (persona que dona las células madre) en el cuerpo de su hijo. Para que un HSCT funcione, las células madre deben provenir de un donante cuyo “tipo de tejido” coincida en forma precisa con el del niño. El tipo de tejido no es lo mismo que el tipo de sangre. Hay millares de tipos diferentes de tejido. El primer paso para obtener un HSCT es encontrar un donante de células madre “compatible”.

#### Localización de un donante de células madre compatible

Por lo común, el donante que mejor coincide en el tipo de tejido es un hermano o una hermana engendrados por los mismos padres. Si su hijo no tiene hermanos ni hermanas o si el tipo de tejido de estos no es compatible, el médico del niño puede ayudarle a buscar un donante no emparentado en los registros de donación de células madre. Estos registros ayudan a vincular a los pacientes que necesitan un trasplante de células madre con voluntarios que ofrecen células madre en donación. Los registros contienen millones de posibles donantes.

#### ¿Cómo se obtienen las células madre del donante?

Las células madre pueden provenir de la médula ósea, la sangre o la sangre del cordón umbilical de donantes.

Si las células madre se toman de la médula ósea, el médico coloca una aguja en el hueso de la cadera del donante para extraer las células madre. Se administra anestesia general al donante para evitar el dolor. Después de que se obtienen las células madre, el donante puede tener dolor durante unos días, en el lugar donde se introdujo la aguja.

Si las células madre se toman de la sangre del donante, éste deberá tomar un tipo de medicamento que aumenta el número de células madre en la sangre. Este medicamento suele administrarse como una inyección diaria durante varios días. Los efectos secundarios del medicamento pueden incluir dolor en músculos o huesos y dolores de cabeza. Una vez que haya suficientes células madre en la sangre del donante, el médico coloca un tubo intravenoso (IV) en una vena grande del brazo del donante o un tubo fino, llamado línea central, en el pecho del donante. Se puede administrar anestesia general al donante, para evitar cualquier dolor. La sangre del donante entra por el tubo y pasa a una máquina que extrae las células madre. El resto de la sangre se devuelve entonces al donante mediante un tubo IV.

Las células madre pueden también provenir de la sangre del cordón umbilical de un donante. La sangre del cordón umbilical se extrae del cordón y la placenta de un bebé después de que nace. Esto no daña en absoluto al bebé. Luego, la sangre del cordón umbilical se congela y se deposita en un banco público de sangre del cordón.

#### Preparación para el HSCT

Antes del HSCT, su hijo necesitará someterse a lo que se llama “acondicionamiento”. El acondicionamiento dura algunos días y consiste en la administración de quimioterapia intensa y a veces radiación. El acondicionamiento es necesario para debilitar drásticamente el sistema inmunológico del niño, de modo que no ataque a las células madre trasplantadas.

El acondicionamiento puede hacer que su hijo se sienta enfermo.

Los efectos secundarios inmediatos pueden incluir:

- Náusea y vómito
- Diarrea
- Pérdida del apetito
- Úlceras en la boca
- Sensación de cansancio
- Pérdida de pelo
- Infección

Algunos tipos de quimioterapia pueden afectar también el corazón y los pulmones.

El acondicionamiento conlleva otros riesgos a largo plazo. Estos riesgos se explican en las páginas 14 y 15.

#### Obtención del HSCT

Para realizar el trasplante, el médico le colocará al niño un tubo fino, llamado línea central, en una vena grande del pecho o un tubo IV en el brazo. Las células madre del donante pasan por el tubo hacia el torrente sanguíneo del niño. El procedimiento puede durar entre 1 y 5 horas y no es doloroso.

Algunos efectos secundarios e inmediatos son:

- Un sabor raro en la boca
- Aliento de olor extraño
- Fiebre o escalofríos
- Presión arterial baja
- Falta de aire
- Opresión o dolor en el pecho
- Urticaria

El HSCT conlleva otros riesgos a largo plazo. Estos riesgos se explican en las páginas 14 y 15.

Las células madre viajan hasta la médula ósea del niño, donde empezarán a multiplicarse y convertirse en células sanguíneas sanas en el transcurso de las semanas siguientes.

#### Después del HSCT

Después del trasplante, es posible que su niño deba permanecer varias semanas en el hospital. Las células madre tardarán algunas semanas en llegar a la médula ósea y empezar a producir nuevas células sanguíneas. Durante ese tiempo, su hijo tendrá una cantidad reducida de células sanguíneas (glóbulos rojos, glóbulos blancos y plaquetas).

Mientras se desarrollan las nuevas células sanguíneas, es posible que el niño necesite antibióticos para prevenir infecciones. También es posible que el niño necesite transfusiones (se le administran glóbulos rojos o plaquetas de sangre donada) y nutrición mediante un tubo intravenoso.

### ¿Qué riesgos conlleva un HSCT?

Un HSCT implica muchos riesgos. Algunos de esos riesgos pueden poner en peligro la vida.

#### Problemas posibles inmediatamente después del HSCT

- Infección: El sistema inmunológico del niño estará muy débil después del HSCT. El sistema inmunológico puede tardar hasta un año o más en volver a lo normal. Durante este tiempo, su hijo corre el riesgo de adquirir una infección grave porque el sistema inmunológico no puede combatir bien a los microbios. El médico puede administrarle antibióticos al niño, para ayudar a prevenir infecciones. La fiebre suele ser el primer signo de infección. Llame inmediatamente al médico si el niño tiene fiebre.
- Sangrado: Después del HSCT, su hijo tendrá una cantidad escasa de plaquetas (las células sanguíneas que ayudan a la coagulación). Pueden necesitarse varias semanas para que se formen nuevas plaquetas. Durante ese tiempo, su hijo puede sangrar o ser propenso a moretones. Si la cuenta plaquetaria disminuye demasiado, el niño puede necesitar una transfusión de plaquetas (se le administran plaquetas de sangre donada).
- Enfermedad de injerto contra huésped (GVHD, por su sigla en inglés): Después de un HSCT, hay cierta posibilidad de que el niño desarrolle GVHD. Esto sucede cuando los nuevos glóbulos blancos (componente importante del sistema inmunológico, que protege el cuerpo contra los microbios) atacan equivocadamente el cuerpo del niño, lo que puede dañar sus órganos. La GVHD puede ser desde leve hasta grave, y a veces pone en peligro la vida. Puede suceder inmediatamente después del trasplante o unos meses después. El primer síntoma de GVHD es un salpullido en las manos o los pies del niño. El médico observará cuidadosamente al niño para detectar signos de esta condición.
- Rechazo del trasplante: Aunque es raro, el cuerpo a veces rechaza las células madre trasplantadas. Esto significa que las células madre trasplantadas no llegaron hasta la médula ósea ni se multiplicaron como se esperaba. El rechazo del trasplante puede poner en peligro la vida y es más frecuente si el tipo de tejido del donante no era totalmente compatible.

#### Problemas que podrían aparecer más adelante

- Recaída: Podrían volver los síntomas de la enfermedad metabólica hereditaria.
- Infertilidad: La quimioterapia o la radiación que se administren a su hijo durante el acondicionamiento previo al HSCT pueden causar infertilidad (no poder tener hijos más adelante en la vida). Tal vez quiera hablar con el médico del niño sobre la recolección de óvulos o la obtención de esperma para guardar en un banco de semen, antes del HSCT.
- Daño a los órganos: La quimioterapia o la radiación que se administren al niño durante el acondicionamiento previo al HSCT pueden dañar sus órganos (como los riñones, el hígado, los pulmones, el corazón o los huesos). Los síntomas de daño a los órganos pueden no aparecer de inmediato.
  - Los órganos que pueden dañarse dependen del tipo específico de quimioterapia y de las dosis de quimioterapia y radiación que haya recibido el niño. El médico del niño le explicará los posibles efectos secundarios a largo plazo a los que debe estar atento.
- Problemas del crecimiento: Un HSCT puede detener el crecimiento de su niño.
- Cáncer: Cualquier persona que reciba un HSCT tiene un riesgo más alto de desarrollar cáncer en el transcurso de su vida. El cáncer podría desarrollarse varios años después del trasplante.

### ¿Qué costo tiene un HSCT?

Un HSCT puede ser muy costoso. Los costos para usted dependen de su seguro médico. Pregunte a su proveedor de seguro médico si su plan cubre el HSCT y cuánto debería pagar usted. Asimismo, pregunte al médico del niño si existen otros recursos que ayuden a cubrir esos gastos.

## Hable con el médico de su hijo

### Pregunte al médico del niño

Puede hacerle al médico del niño las siguientes preguntas. Muchas de estas preguntas podrá responderlas mejor un médico que tenga experiencia con los HSCT.

- ¿Cuáles son los beneficios y los riesgos posibles de un HSCT para mi hijo?
- ¿Cuál es la probabilidad de que un HSCT pueda ayudar a mi hijo?
- ¿Podría un HSCT curar a mi hijo o solamente aliviar sus síntomas?
- ¿Qué probabilidad hay de que la enfermedad de mi niño se repita después del HSCT?
- ¿Cómo encontraremos un donante de células madre para mi hijo?
- ¿Cómo debemos prepararnos para el trasplante?
- ¿Qué sucederá después del trasplante?
- ¿Cuánto tiempo deberá mi hijo permanecer en el hospital?
- ¿Qué efectos secundarios graves debo buscar y cuándo debo avisarle al respecto?
- ¿A qué problemas graves debemos estar atentos más adelante en la vida de mi niño?

## Fuente

La información de este resumen proviene del informe Hematopoietic Stem-Cell Transplantation in the Pediatric Population (Trasplante de células madre hematopoyéticas en la población pediátrica), de febrero de 2012. Fue producido por el Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro de Evaluación de Tecnología de la Blue Cross and Blue Shield Association), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/stem-cell-children.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus®, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas) en el Baylor College of Medicine (Facultad de Medicina de Baylor), en Houston, Texas. Este resumen fue revisado por padres o personas que ayudan al cuidado de niños que han recibido un trasplante de médula ósea o de células madre sanguíneas.

Esta guía fue traducida de la publicación en inglés titulada Bone Marrow or Blood Stem Cell Transplants in Children With Certain Rare Inherited Metabolic Diseases: A Review of the Research for Parents and Caregivers.

* Enfermedades de Wolman, de Farber, de Niemann-Pick y de Gaucher, lipofuscinosis ceroide neuronal infantil temprana y síndromes de Hunter o de Sanfilippo