# Trasplantes de médula ósea o de células madre sanguíneas en niños con formas graves de trastornos autoinmunes o ciertos tipos de cáncer

Revisión de la investigación para padres y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Esta información es para usted si

- El médico del niño ha dicho que tiene una de las siguientes enfermedades:
  - Una forma muy grave de uno de los siguientes trastornos autoinmunes, para el cual ningún otro tratamiento ha sido eficaz.
    – Lupus sistémico eritematoso
    – Esclerosis sistémica
    – Esclerosis múltiple maligna
    – Artritis idiopática juvenil
    – Enfermedad de Crohn
  - Uno de los siguientes tipos de cáncer.
    – Astrocitoma de una etapa intermedia que siguió creciendo después de tratamiento o reapareció
    – Rabdomiosarcoma que se ha diseminado a otras partes del cuerpo
    – Retinoblastoma que se ha diseminado al cerebro y la médula espinal
    – Familia de tumores del sarcoma de Ewing
    – Tumor de Wilms que reapareció después de tratamiento
    – Ependimoma
- El médico de su hijo le ha hablado de un trasplante de células madre hematopoyéticas (HSCT, por su sigla en inglés) en el que se utilizan las células madre del propio niño. Puede llamarse también trasplante de células madre sanguíneas o trasplante de médula ósea.
- Su hijo tiene menos de 21 años de edad. La información de este resumen proviene de investigaciones en niños menores de 21 años.

Nota: Un trasplante de médula ósea o de células madre sanguíneas puede tener efectos secundarios graves. En la investigación para este resumen, el trasplante de células madre se hizo solamente en pacientes con una forma muy grave de la enfermedad, cuando ningún otro tratamiento había sido eficaz. Este resumen cubre solamente los trasplantes en que se utilizan las células madre del niño y no las células madre de un donante.

Nota: El HSCT puede no ser útil en todos los niños con una de estas enfermedades. Vea en la página 6 (formas muy graves de trastornos autoinmunes) o la 9 (tipos de cáncer) lo que los investigadores han encontrado sobre el tratamiento de cada enfermedad mediante un HSCT en el que se utilizan las células madre del propio niño.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Información sobre cada trastorno autoinmune y tipo de cáncer
- Beneficios posibles de un HSCT
- Lo que han encontrado los investigadores acerca de niños con una forma muy grave de una de estas enfermedades que recibieron un HSCT en el que se usaron sus propias células madre
- Qué es un HSCT y cómo se realiza
- Riesgos posibles de un HSCT

Este resumen puede ayudarle a hablar con el médico para saber si un HSCT podría ayudar a su niño.

### ¿De dónde proviene la información?

Los investigadores revisaron estudios acerca de los HSCT en niños con diferentes enfermedades. Esos estudios se publicaron entre enero de 1995 y agosto de 2011. Los investigadores fueron financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal.

Los investigadores escribieron un informe sobre lo que encontraron y este resumen se basa en ese informe. El informe fue revisado por médicos, investigadores, otros expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/stem-cell-children.cfm (disponible sólo en inglés).

## Conozca la condición de su hijo: Formas muy graves de trastornos autoinmunes

### ¿Qué son los trastornos autoinmunes y cómo puede ayudar un HSCT?

Los trastornos autoinmunes son enfermedades en las que el sistema inmunológico (el sistema que protege al cuerpo contra los microbios) no funciona como debe. En las personas que padecen un trastorno autoinmune, el sistema inmunológico ataca por error a las células y los tejidos sanos. Esto puede dañar los órganos u otras partes del cuerpo.

En un niño con una forma muy grave de una enfermedad autoinmune, el propósito de un HSCT es restaurar el sistema inmunológico del niño. Después del HSCT, se espera que el sistema inmunológico deje de atacar a las células y tejidos sanos del cuerpo del niño.

El primer paso en un HSCT es recolectar células madre de la sangre o de la médula ósea del niño. Luego, los glóbulos blancos (componente importante del sistema inmunológico) se destruyen utilizando quimioterapia y a veces radiación. Después, las células madre se devuelven al interior del cuerpo del niño. Los glóbulos blancos que se desarrollan a partir de las células madre trasplantadas se multiplican hasta reconstituir el sistema inmunológico del niño.

En las páginas siguientes se ofrece una breve descripción de los trastornos autoinmunes que cubre este resumen.

Nota: El presente resumen cubre solamente el uso de los HSCT en niños con formas muy graves de estos trastornos autoinmunes cuando ningún otro tratamiento ha sido eficaz. Asimismo, este resumen trata solamente de los HSCT en que se utilizan las células madre del niño y no células madre de donantes.

#### Lupus sistémico eritematoso

El lupus sistémico eritematoso es una enfermedad que causa daño a la piel, los vasos sanguíneos, las articulaciones y a órganos importantes como el corazón, los pulmones, los riñones y el cerebro.

##### Los síntomas pueden incluir

- Un salpullido rojizo en la piel
- Dolor o hinchazón de las articulaciones
- Fiebre
- Cansancio extremo
- Dolor muscular
- Dolor abdominal
- Falta de aire
- Convulsiones
- Dolor de pecho
- Sangre en la orina
- Insuficiencia renal
- Derrame cerebral

#### Esclerosis sistémica

La esclerosis sistémica es una enfermedad que hace que los tejidos corporales se endurezcan o se engrosen.

La esclerosis sistémica puede dañar la piel, los tejidos subcutáneos (debajo de la piel), los vasos sanguíneos y órganos importantes como el corazón, los pulmones y los riñones. Esta enfermedad es más frecuente en las niñas que en los niños.

##### Los síntomas pueden incluir

- Comezón y dureza en zonas de la piel
- Hinchazón o dolor de las articulaciones
- Hinchazón de dedos y manos
- Acidez estomacal
- Cansancio
- Palidez en los dedos, los pies y las manos cuando se siente frío o ansiedad (llamado fenómeno de Raynaud)

#### Esclerosis múltiple maligna

La esclerosis múltiple maligna es una forma grave y poco frecuente de esclerosis múltiple que empeora muy rápidamente. La esclerosis múltiple es una enfermedad que afecta al cerebro y la médula espinal. Esta enfermedad es más frecuente en las niñas que en los niños.

##### Los síntomas pueden incluir

- Problemas de la vista
- Debilidad muscular
- Mareos
- Dificultad con el equilibrio y las tareas que requieren coordinación
- Sensación de entumecimiento u hormigueo
- Problemas de la memoria y el razonamiento
- Cansancio

#### Artritis idiopática juvenil

La artritis idiopática juvenil es una enfermedad que causa hinchazón, dolor y rigidez de las articulaciones en los niños. Esta enfermedad puede ser leve o grave y puede dañar las articulaciones. Puede también afectar el corazón y los pulmones del niño y causar problemas del crecimiento.

##### Los síntomas pueden incluir

- Cojera
- Hinchazón, dolor o rigidez de las articulaciones
- Salpullido en la piel
- Fiebre
- Inflamación de glándulas

#### Enfermedad de Crohn

La enfermedad de Crohn causa inflamación en los intestinos. Puede también causar inflamación en la boca y en el recto.

##### Los síntomas pueden incluir

- Cólicos o dolor abdominal
- Dolor al defecar
- Diarrea
- Sangrado del recto
- Pérdida de peso
- Fiebre

¿Qué han encontrado los investigadores acerca del tratamiento con HSCT en los niños que tienen formas muy graves de trastornos autoinmunes?

Trastorno autoinmune | Número de pacientes estudiados en la investigación | Los investigadores encontraron lo siguiente acerca del HSCT que utiliza células madre del propio niño para tratar una forma muy grave del trastorno cuando ningún otro tratamiento ha sido eficaz:
Lupus sistémico eritematoso | 17 pacientes | - Los síntomas mejoraron lo suficiente como para que el niño no tomara medicamentos para su trastorno durante varios meses y hasta varios años, dependiendo del trastorno.; - No existe suficiente investigación para saber qué tan eficaz es el HSCT a largo plazo para tratar a niños con un trastorno autoinmune grave. También pueden haber varios efectos secundarios a largo plazo (vea las páginas 14 y 15).
Esclerosis sistémica | 43 pacientes
Esclerosis múltiple maligna | 5 pacientes
Artritis idiopática juvenil | 5 pacientes
Enfermedad de Crohn | 7 pacientes

Nota: Es importante advertir que los resultados de estas investigaciones se basan en un número muy pequeño de estudios efectuados en niños con formas muy graves de estos trastornos autoinmunes cuando ningún otro tratamiento había sido eficaz. Pregunte al médico de su hijo si estos resultados de investigación tienen validez para su hijo y si un HSCT podría ayudar al niño.

## Conozca la condición de su hijo: Cáncer

### ¿Qué son los tumores cancerosos y cómo puede ayudar un HSCT?

Un tumor se forma cuando las células se reproducen de manera descontrolada. Algunos tumores crecen solamente en el lugar donde se forman y no se diseminan a otras partes del cuerpo. Se les llama tumores “benignos” (no cancerosos). Un tumor que es canceroso puede diseminarse a otras partes del cuerpo y dañar los órganos, lo que puede poner en peligro la vida.

En un niño con cáncer, el propósito de un HSCT es permitir que los médicos utilicen quimioterapia y posiblemente radioterapia intensas con la intención de destruir las células del tumor canceroso. La quimioterapia y la radiación también destruyen las células sanguíneas sanas del niño. Antes de la quimioterapia y la radioterapia, se obtienen células madre de la sangre o la médula ósea del niño. Después del tratamiento, las células madre del niño se devuelven al interior del cuerpo para reconstruir las células sanguíneas.

Este resumen cubre el uso de los HSCT en niños con uno de los siguientes tipos de cáncer:

- El astrocitoma es un tipo de cáncer del cerebro o la médula espinal. Este resumen cubre el uso de los HSCT en niños con astrocitoma que está en etapa intermedia y que siguió creciendo durante el tratamiento o que resurgió después de éste.
- El rabdomiosarcoma es un tipo de cáncer de los músculos, los tendones, la grasa o los vasos sanguíneos. Este resumen cubre el uso de los HSCT en niños con rabdomiosarcoma que se ha diseminado (fase de “metástasis”) a otras partes del cuerpo.
- El retinoblastoma es un tipo de cáncer del ojo. Este resumen cubre el uso de los HSCT en niños con retinoblastoma que se ha diseminado (fase de “metástasis”) al cerebro y a la médula espinal.
- La familia de tumores del sarcoma de Ewing es un tipo de cáncer óseo que ocurre en los huesos o en otras partes del cuerpo. Este resumen cubre el uso de los HSCT en niños con uno de estos tumores.
- El tumor de Wilms es un tipo de cáncer del riñón. Este resumen cubre el uso de los HSCT en niños con tumor de Wilms que resurgió después del tratamiento.
- El ependimoma es un tipo de cáncer que afecta al cerebro o la médula espinal. Este resumen cubre el uso de los HSCT en niños con este tipo de cáncer.

¿Qué han encontrado los investigadores acerca del tratamiento con HSCT en los niños que tienen ciertos tipos de cáncer?

Tipo raro de cáncer | Número de pacientes en la investigación que fueron estudiados y que recibieron un HSCT | HSCT en el que se usan células madre del propio niño:
Astrocitoma que está en etapa intermedia y sigue creciendo durante el tratamiento o resurgió después de éste | 10 pacientes | Puede aumentar la probabilidad de sobrevivir 5 años en comparación con el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza
Rabdomiosarcoma que se ha diseminado a otras partes del cuerpo | 346 pacientes | No aumentó la probabilidad de sobrevivir en comparación con el tratamiento usual^*^
Retinoblastoma que se ha diseminado al cerebro y a la médula espinal | 91 pacientes | Al parecer, no aumentó la probabilidad de sobrevivir en comparación con el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza
Familia de tumores del sarcoma de Ewing | 446 pacientes | Al parecer, no aumentó la probabilidad de sobrevivir en comparación con el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza
Tumor de Wilms que resurgió después del tratamiento | 114 pacientes | Al parecer, no aumentó la probabilidad de sobrevivir en comparación con el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza
Ependimoma | 215 pacientes | Puede disminuir la probabilidad de sobrevivir en comparación con el tratamiento usual^*^, pero se necesita más investigación para saberlo con certeza

* El tratamiento usual difiere según el tipo de cáncer. Pregunte al médico del niño cuál es el tratamiento usual para el cáncer de su hijo.

Nota: Es importante advertir que estos resultados de investigación se basan en un número muy pequeño de estudios de niños con estos tipos de cáncer. Pregunte al médico de su hijo si estos resultados de investigación tienen validez para su hijo y si un HSCT podría ayudar a su niño.

## Aprenda sobre el trasplante de células madre hematopoyéticas

### ¿Qué son las células madre hematopoyéticas?

Las células madre hematopoyéticas son células jóvenes que al desarrollarse se convierten en células sanguíneas. Existen tres tipos de células sanguíneas:

- Los glóbulos rojos transportan oxígeno a todo el cuerpo.
- Los glóbulos blancos son parte importante del sistema inmunológico, que protege al cuerpo contra los microbios.
- Las plaquetas ayudan a la sangre a coagular.

Las células madre se encuentran principalmente en la médula ósea (el tejido esponjoso dentro de los huesos). En la médula ósea, las células madre se multiplican y se desarrollan hasta convertirse en células sanguíneas. Cuando las células sanguíneas completan su desarrollo, abandonan la médula ósea y entran en el torrente sanguíneo. Algunas células madre pueden encontrarse también en el torrente sanguíneo.

Nota: Las células madre hematopoyéticas no son células madre tomadas de un embrión (un óvulo humano fecundado por espermatozoides) y no son lo mismo que las células madre que se utilizan en la clonación.

### ¿Cuál es el proceso para obtener un HSCT?

#### Obtención de las células madre

Las células madre pueden provenir de la sangre, la médula ósea o la sangre del cordón umbilical del niño.

Si las células madre se obtendrán de la sangre del niño, éste deberá tomar un tipo de medicamento que aumenta el número de células madre en la sangre. Este medicamento suele administrarse como una inyección diaria durante varios días. Los efectos secundarios del medicamento pueden incluir dolor en músculos o huesos y dolores de cabeza. Una vez que haya suficientes células madre en la sangre del niño, el médico colocará un tubo intravenoso (IV) en una vena grande del brazo del niño o un tubo fino, llamado línea central, en su pecho. Se puede administrar al niño anestesia general, para evitar el dolor. La sangre del niño entra por el tubo y pasa a una máquina que extrae las células madre. El resto de la sangre se devuelve entonces al niño por medio del tubo.

Si las células madre se tomarán de la médula ósea, el médico colocará una aguja en la parte posterior del hueso de la cadera del niño para extraer las células madre. Se administrará al niño anestesia general para evitar el dolor. Después de obtener las células madre, el niño puede tener dolor durante unos días, en el lugar donde se introdujo la aguja.

Las células madre pueden también provenir de la sangre del cordón umbilical. Cuando su hijo nació, es posible que se haya extraído sangre del cordón umbilical y de la placenta. Si la sangre del cordón umbilical de su hijo fue congelada y almacenada en un banco de sangre del cordón, es posible que el médico pueda utilizar células madre de la sangre del cordón del niño para el HSCT.

#### Preparación para el HSCT

Antes del HSCT, su hijo necesitará someterse a lo que se llama “acondicionamiento”. El acondicionamiento consiste en quimioterapia y a veces radiación, intensas. En niños con formas muy graves de trastornos autoinmunes, se requiere el acondicionamiento para destruir los glóbulos blancos defectuosos del niño. En los niños con cáncer, el acondicionamiento es necesario para tratar de destruir las células cancerosas en el cuerpo del niño.

El tratamiento de acondicionamiento puede hacer que su hijo se sienta enfermo.

Los efectos secundarios inmediatos pueden incluir:

- Náusea y vómito
- Diarrea
- Pérdida del apetito
- Úlceras en la boca
- Cansancio
- Pérdida del cabello
- Infección

Algunos tipos de quimioterapia pueden afectar también el corazón y los pulmones.

El acondicionamiento conlleva otros riesgos a largo plazo. Estos riesgos se explican en las páginas 14 y 15.

#### Obtención del HSCT

Para realizar el trasplante, el médico le colocará al niño un tubo fino, llamado línea central, en una vena grande del pecho o un tubo intravenoso (IV) en el brazo. Las células madre pasan por el tubo hacia el torrente sanguíneo del niño. El procedimiento puede durar de 1 a 5 horas y no es doloroso.

Los efectos secundarios inmediatos pueden incluir:

- Un sabor raro en la boca
- Aliento de olor extraño
- Fiebre o escalofríos
- Presión arterial baja
- Falta de aire
- Opresión o dolor en el pecho
- Urticaria (ronchas en la piel)

El HSCT conlleva otros riesgos a largo plazo. Estos riesgos se explican en las páginas 14 y 15.

Las células madre viajan hasta la médula ósea del niño, donde empezarán a multiplicarse y convertirse en células sanguíneas en el transcurso de las semanas siguientes.

#### Después del HSCT

Después del trasplante, es posible que su niño deba permanecer varias semanas en el hospital. Las células madre tardarán algunas semanas en entrar en la médula ósea y empezar a producir nuevas células sanguíneas. Durante ese tiempo, su hijo tendrá una cantidad pequeña de células sanguíneas (glóbulos rojos, glóbulos blancos y plaquetas).

Mientras se desarrollan las nuevas células sanguíneas, es posible que el niño necesite antibióticos para prevenir infecciones. También es posible que el niño necesite transfusiones (se le administran glóbulos rojos o plaquetas de sangre donada) y nutrición mediante un tubo intravenoso.

### ¿Qué riesgos conlleva un HSCT?

Un HSCT implica muchos riesgos. Algunos de esos riesgos pueden poner en peligro la vida.

#### Problemas posibles inmediatamente después del HSCT

- Infección: El sistema inmunológico del niño estará muy débil después del HSCT. El sistema inmunológico puede tardar hasta un año o más en volver a lo normal. Durante este tiempo, su hijo corre el riesgo de adquirir una infección grave porque el sistema inmunológico no puede combatir bien a los microbios. El médico puede administrarle antibióticos al niño, para ayudar a prevenir infecciones. La fiebre suele ser el primer signo de infección. Llame inmediatamente al médico si el niño tiene fiebre.
- Sangrado: Después del HSCT, su hijo tendrá una cantidad escasa de plaquetas (las células sanguíneas que ayudan a la coagulación). Pueden tardar varias semanas en formarse nuevas plaquetas. Durante ese tiempo, su hijo puede sangrar fácilmente o ser propenso a que se formen moretones. Si la cuenta plaquetaria disminuye demasiado, el niño puede necesitar una transfusión de plaquetas (se le administran plaquetas de sangre donada por medio de un tubo IV).

#### Problemas que podrían aparecer más adelante

- Recaída: En los niños con un trastorno autoinmune, los síntomas del trastorno pueden resurgir. En los niños con cáncer, éste puede reaparecer.
- Infertilidad: La quimioterapia o la radiación que se administren a su hijo durante el acondicionamiento pueden causar infertilidad (no poder tener hijos más adelante en la vida). Tal vez quiera hablar con el médico del niño sobre la recolección de óvulos o la obtención de esperma para guardar en un banco de semen, antes del HSCT.
- Daño a los órganos: La quimioterapia y la radiación que se administren al niño durante el acondicionamiento pueden dañar sus órganos (como los riñones, el hígado, los pulmones, el corazón o los huesos). Los síntomas de daño a los órganos pueden no aparecer de inmediato.
  - Los órganos que pueden dañarse dependen del tipo específico de quimioterapia y de las dosis de quimioterapia y radiación que haya recibido el niño. El médico del niño le explicará los posibles efectos secundarios a largo plazo a los que debe estar atento.
- Problemas del crecimiento: Un HSCT puede detener el crecimiento de su niño.
- Cáncer (un cáncer nuevo o segundo cáncer): Cualquier persona que reciba un HSCT tiene un riesgo más alto de desarrollar cáncer en el transcurso de su vida. El cáncer podría desarrollarse varios años después del trasplante. En niños cuyo cáncer se trató con éxito mediante un HSCT, puede desarrollarse un cáncer nuevo y de tipo diferente.

## ¿Qué costo tiene un HSCT?

Un HSCT puede ser muy costoso. Los costos para usted dependen de su seguro médico. Pregunte a su proveedor de seguro médico si su plan cubre el HSCT y cuánto debería usted pagar. Asimismo, pregunte al médico del niño si existen otros recursos que ayuden a cubrir esos gastos.

## Hable con el médico de su hijo

### Pregunte al médico del niño

Puede hacerle al médico del niño las siguientes preguntas. Muchas de estas preguntas podrá contestarlas mejor un médico que tenga experiencia con los HSCT.

- ¿Cuáles son los beneficios y los riesgos posibles de un HSCT para mi hijo?
- ¿Cuál es la probabilidad de que un HSCT pueda ayudar a mi hijo?
- ¿Podría un HSCT curar a mi hijo o solamente aliviar sus síntomas?
- ¿Qué probabilidad hay de que los síntomas (o el cáncer) de mi niño se repitan después del HSCT?
- ¿Cómo debemos prepararnos para el trasplante?
- ¿Qué debemos esperar después del trasplante?
- ¿Cuánto tiempo deberá mi hijo permanecer en el hospital?
- ¿A qué efectos secundarios graves debemos estar atentos y cuándo debo avisarle al respecto?
- ¿A qué problemas graves posibles debemos estar atentos más adelante en la vida del niño?

## Fuente

La información de este resumen proviene del informe Hematopoietic Stem-Cell Transplantation in the Pediatric Population (Trasplante de células madre hematopoyéticas en la población pediátrica), de febrero de 2012. El informe fue producido por el Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro de Evaluación de Tecnología de la Blue Cross and Blue Shield Association), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/stem-cell-children.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas) en el Baylor College of Medicine (Facultad de Medicina de Baylor), en Houston, Texas. Este resumen fue revisado por padres o personas que ayudan al cuidado de niños que han recibido un trasplante de médula ósea o de células madre sanguíneas y por adultos jóvenes que recibieron un trasplante de médula ósea o de células madre sanguíneas durante su adolescencia.

Esta guía fue traducida de la publicación en inglés titulada Bone Marrow or Blood Stem Cell Transplants in Children With Severe Forms of Autoimmune Disorders or Certain Types of Cancer: A Review of the Research for Parents and Caregivers.