# Cómo medir la presión arterial en casa

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Un médico^*^ le ha dicho que es posible que tenga presión arterial alta, también llamada “hipertensión”.
- El médico le sugirió que se mida regularmente la presión arterial en su casa.
- Usted quiere saber más acerca de la opción de medirse la presión arterial en casa.

¿Qué información ofrece este resumen?

Este resumen le ayudará a aprender cómo se mide la presión arterial en casa. Se escribió para ayudarles a usted y a su médico a decidir si es conveniente que se mida la presión arterial en casa. Este resumen le informará también de las investigaciones sobre los monitores para la presión arterial y le sugerirá preguntas que puede hacerle a su médico.

Se hizo una revisión de 49 estudios de investigación, para la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés), una agencia de investigación del gobierno federal. La revisión se hizo para comprender si hay beneficios al medirse uno mismo la presión arterial. El informe fue revisado por médicos clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/selfmeasuredbp.cfm (disponible sólo en inglés).

En este resumen no se habla de los medicamentos que se usan para tratar la presión arterial alta.

## Conozca su condición

### ¿Qué es la presión arterial alta?

La presión arterial alta, llamada también “hipertensión”, es una condición médica seria. Sucede cuando la sangre se bombea con demasiada fuerza a través de las arterias.

Cuando el corazón late, impulsa la sangre por las arterias hacia el resto del cuerpo. Cuando la sangre empuja con demasiada fuerza las paredes arteriales, la presión arterial aumenta. La presión arterial puede variar según la hora del día. Por lo general es más alta cuando la persona despierta, después de hacer ejercicio o en situaciones de estrés.

Es normal que la presión se eleve por tiempos breves. Sin embargo, cuando la presión se mantiene elevada la mayor parte del tiempo, puede causar problemas graves de salud.

### ¿Qué tan común es la presión arterial alta?

- La presión alta crónica (constante) es una condición de salud común.
- La presión arterial alta afecta a los adultos de todas las edades, pero principalmente a los mayores de 65 años.
- En Estados Unidos, cerca de 76.4 millones de personas tienen la presión arterial alta.

Cuando disminuye la presión arterial, también se reduce el riesgo de que ocurra un ataque al corazón, insuficiencia cardiaca, derrames u otros problemas de salud. Cada año, cerca de 7 millones de personas mueren en Estados Unidos debido a enfermedades causadas por la presión arterial alta.

### ¿Qué problemas puede causar la presión arterial alta?

- Tener presión arterial alta durante mucho tiempo puede dañar el corazón y ocasionar insuficiencia cardiaca.
- Si la presión arterial alta no se trata, puede causar un ataque al corazón, derrames, falla del riñón (insuficiencia renal) u otros problemas de salud graves.

Cuando se tiene la presión arterial alta, lo más peligroso es no saberlo o buscar tratamiento. Cuando usted sabe que tiene la presión arterial alta y busca un tratamiento, puede disminuir el riesgo de tener algunos de los problemas que ésta causa.

## Medición de la presión arterial

### ¿Cómo se mide la presión arterial?

Usualmente, se llena de aire un brazalete, que aprieta la arteria de la parte superior del brazo, de modo que al dejar escapar el aire del brazalete, un indicador (instrumento para medir) registra la medida de la presión arterial. En la mayoría de los aparatos para uso casero, los indicadores son pantallas digitales (electrónicas).

#### ¿Qué significan los números?

La medición de la presión arterial tiene dos partes: el número de arriba (o primero) y el número de abajo (segundo). El número de arriba es la presión “sistólica” y el número de abajo, la presión “diastólica”.

- La presión sistólica es la presión arterial cuando el corazón late y bombea la sangre a través de las arterias. La presión es más alta cuando el corazón está bombeando; por eso el número sistólico siempre es más alto.
- La presión diastólica es la presión arterial entre latidos cardiacos, cuando el corazón no está bombeando. La presión arterial es más baja cuando el corazón no está bombeando; por eso el número diastólico es más bajo.

Los números de su presión arterial se presentan uno arriba del otro, con la presión sistólica “arriba” de la presión diastólica.

- La presión arterial normal es menor de “120 sobre 80”, o sea 120/80. Eso significa que la presión sistólica es de 120 y la diastólica de 80.
- Una presión arterial entre 120/80 y 139/89 se llama “prehipertensión”. Esto significa que su presión arterial es más alta de lo normal y que corre el riesgo de padecer de presión arterial alta.
- Si su presión arterial es de 140/90 o más, la mayoría de las veces que se la mide, entonces usted padece de presión arterial alta.

### ¿Para qué se mide la presión arterial?

La única manera de saber si la presión arterial está alta, es midiéndola regularmente, varias veces al día y durante varios meses. La presión arterial alta puede no causar ningún síntoma; por ello es importante medir la presión regularmente, aun cuando no se sienta que está alta.

Para ayudarle a llevar un mejor control de su presión arterial, su médico puede sugerir que se la mida regularmente en casa. Su médico puede indicarle cuántas veces al día debe medirla y a qué horas.

### ¿Qué dicen las investigaciones?

- El medirse la presión arterial en casa ayudó a algunas personas a bajar un poco su presión; entre dos y tres puntos, tanto para el número de arriba (o primero) como para el de abajo (segundo). No existen investigaciones suficientes para saber si los cambios duraron más de 6 meses.
- Las personas que recibían algún tipo de apoyo, de su médico o clínica, para medirse la presión arterial también mejoraron el control de su presión. No existen suficientes investigaciones para saber si los cambios duraron más de 1 año.
- No existe suficiente investigación para saber si el medirse la presión arterial en casa, con o sin apoyo adicional (como cursos o recordatorios telefónicos) ha ayudado a las personas a reducir el número de medicamentos que tenían que tomar, la cantidad de cada medicamento que tenían que tomar, o el número de veces que necesitaron acudir a un médico. Los investigadores no han establecido qué tipo de apoyo adicional, de un médico o clínica, sería mejor para ayudar a las personas a medirse la presión arterial en casa.

El medirse la presión arterial no es un tratamiento para la presión alta. Para ayudar a tratar la presión alta, tal vez necesite llevar una alimentación sana, mantener un peso saludable, hacer suficiente ejercicio y no fumar. Su médico puede también recomendarle medicamentos para ayudarle a bajar la presión arterial. El medirse la presión arterial regularmente es sólo una parte del plan para que reduzca la presión arterial alta.

### ¿Qué aparatos hay disponibles para medir la presión arterial en casa?

Si a usted y a su médico les parece una buena idea que se mida la presión arterial en casa, usted deberá comprar el equipo. Puede comprar, sin receta, un monitor de presión arterial casero en una farmacia u otra tienda que venda suministros médicos. También en Internet hay tiendas que venden monitores caseros para medir la presión arterial. Hay distintos tipos de monitores, pero todos tienen las mismas partes principales:

- Un brazalete inflable que se pone alrededor del brazo. Algunos aparatos inflan el brazalete automáticamente, mientras que otros necesitan que se les bombee aire manualmente.
- Un indicador con números y manecilla, o una pantalla digital, que muestran la lectura de su presión arterial.

Algunos monitores de presión arterial tienen un “estetoscopio” (el instrumento que usa el médico para escuchar el corazón). No todos los monitores necesitan estetoscopio para medir la presión arterial.

### Hay tres tipos de monitores caseros para medir la presión arterial

#### Monitores automáticos

- Encienda el monitor pulsando un botón. El brazalete se infla por sí solo.
- Su presión arterial se detecta a medida que el brazalete se desinfla y le muestra la medición.

#### Monitores semiautomáticos

- Con el monitor semiautomático, uno mismo infla y desinfla el brazalete que se coloca en el brazo. La presión arterial se muestra con una lectura digital.

#### Monitores manuales

- Infle el brazalete bombeando aire con la pera de goma que está conectada al tubo.
- Use después un estetoscopio para escuchar el sonido de la sangre que fluye por la arteria, mientras deja que la presión del brazalete vaya bajando lentamente.

## Selección de un monitor de presión arterial casero

### ¿Qué tipo de monitor funciona mejor?

No existe suficiente investigación para afirmar que un tipo de monitor casero funcione mejor que otro para medir con exactitud la presión arterial. El buen funcionamiento de un monitor puede depender de lo bien que aprenda usted a utilizarlo. Llévele su monitor a su médico o enfermera para que puedan:

- Mostrarle cómo usarlo.
- Revisar el monitor para verificar que da la misma medición.

#### ¿Qué es importante considerar al escoger un monitor?

- El monitor debe tener instrucciones claras y ser fácil de usar. El brazalete debe ajustarse bien en su brazo. Si el brazalete no ajusta bien, no dará una lectura correcta. Antes de comprar el monitor, tal vez quiera verificar que el brazalete no sea demasiado grande o pequeño para su brazo. El indicador con manecilla o la pantalla del monitor deben ser lo suficientemente grandes para que usted pueda ver con claridad.
- Si el monitor viene con un estetoscopio, éste debe caberle bien en los oídos, para que usted pueda oír claramente. Necesitará saber lo que significan los sonidos. Pregunte a su médico o enfermera cómo se usa el estetoscopio.

#### ¿Cuánto cuestan los monitores caseros para medir la presión arterial?

Un monitor casero para presión medir la arterial puede costar entre $40 y $150. Los monitores manuales básicos suelen costar menos. Los monitores automáticos con características avanzadas (como la capacidad de guardar las lecturas, imprimirlas o enviarlas electrónicamente a su médico) son más costosos. Ya que es posible que su seguro médico no cubra el costo de un monitor casero, verifique con su seguro médico qué tipos o marcas estarían cubiertos, si lo están.

### Pregunte a su médico

Su médico puede ayudarle a decidir si el medirse la presión arterial en casa puede ser de ayuda. Pregunte a su médico:

- ¿Considera usted que medirme la presión arterial en casa me ayudaría a controlarla mejor?
- ¿Podría usted, o alguien del consultorio, enseñarme a usar mi monitor de presión arterial? Si no es posible, ¿dónde podría aprender a usarlo correctamente?
- ¿Cuántas veces al día, o a la semana, debo medirme la presión arterial?
- ¿Son algunas horas del día mejores que otras para medirme la presión arterial?
- ¿Debo anotar los números cada vez que me mida la presión?
- ¿Quiere usted que le muestre los números?
- ¿Debo cambiar la cantidad de medicamento que tomo de acuerdo con mis números?
- ¿Qué números me indicarían si necesito venir a verlo o buscar ayuda inmediata?

### Anote aquí las respuestas

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

_________________________________________________________________________

## Fuente

La información de este resumen proviene del informe Self-Measured Blood Pressure Monitoring: Comparative Effectiveness (Monitoreo de la presión arterial por automedición: comparación de la efectividad) de enero de 2012.

El informe fue producido por el Tufts University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Tufts), con el financiamiento de la Agency for Healthcare Research and Quality (AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/selfmeasuredbp.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web de MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con presión arterial alta.

Traducido de la publicación en inglés titulada Measuring Your Blood Pressure at Home: A Review of the Research for Adults.

* En este resumen, la palabra “médico” se refiere a cualquier profesional de la atención médica que pueda atenderlo, lo que incluye a su médico, enfermera o asistente médico.