# Opciones para tratar el desgarro de los músculos y tendones del hombro

Guía para adultos con lesiones en el manguito de los rotadores

## ¿Es esta guía apropiada para mí?

- SÍ lo es, si su médico le dijo que tiene un desgarro del manguito de los rotadores, que es una lesión de uno o más músculos y tendones del hombro.
- NO lo es, si tiene usted algún otro tipo de lesión del hombro o la parte alta de la espalda, o una lesión no relacionada con el manguito de los rotadores. Pregunte a su médico si esta guía es apropiada para usted.

Esta guía le explicará lo que las investigaciones han descubierto sobre las diversas opciones para tratar el desgarro del manguito de los rotadores. Le puede ayudar a usted y a su médico o a otro personal de salud (enfermera, asistente médico, experto en terapia física o fisioterapeuta) a analizar y decidir qué tratamientos le convienen más.

### ¿Cuál es la fuente de esta guía?

La información de esta guía se deriva de una revisión de muchos estudios diferentes acerca de los tratamientos para el desgarro del manguito de los rotadores. No se basa en un solo estudio, sino en muchos estudios, considerados en conjunto por un equipo de investigadores, médicos y otros expertos.

## Conozca su condición

### ¿Qué es el manguito de los rotadores?

El manguito de los rotadores es un grupo de cuatro músculos que surgen de la paletilla (escápula u omóplato) de la espalda, con tendones que se fijan en la cabeza o bola del húmero (el hueso de la parte superior del brazo).

Estos músculos y tendones le ayudan a levantar y girar los brazos. También ayudan a mantener firmemente alojada la bola del húmero en la cavidad del hombro.

### ¿Qué es un desgarro del manguito de los rotadores?

Los tendones de su manguito de los rotadores pueden desgarrarse como lo haría un pedazo de cuero. A veces, el tendón se daña o se irrita sólo levemente. En otros casos, el tendón sufre un desgarro completo, lo que significa que el tendón se desprendió del hueso.

### ¿Qué causa el desgarro del manguito de los rotadores?

Los tendones del manguito de los rotadores pueden desgarrarse por una variedad de razones:

- Una lesión, como una caída o golpe en el hombro.
- Uso excesivo, con acciones repetidas durante mucho tiempo, como levantar objetos, pintar, limpiar ventanas o lanzar.
- Desgaste natural y desgarro por envejecimiento.

### Cómo afecta su vida un desgarro del manguito de los rotadores

Un desgarro del manguito de los rotadores no pone en peligro la vida, pero puede limitar el movimiento y causar dolor.

#### Movimiento limitado

Incluso los pequeños movimientos del hombro y el brazo, como peinarse, ponerse una chaqueta o cargar los comestibles, pueden ser difíciles y causar dolor.

#### Dolor

El dolor puede variar desde leve o moderado hasta agudo. El dolor puede sentirse arriba y en la parte frontal del hombro lesionado. Puede extenderse por la cara externa de la parte superior del brazo. Su dolor puede ser más fuerte por la noche, sobre todo cuando uno se acuesta sobre el hombro lesionado.

#### Hinchazón

La hinchazón causada por inflamación es una reacción natural del cuerpo a las lesiones. A veces, puede ocurrir hinchazón dentro del cuerpo sin que uno lo note. Esa hinchazón es la causa más común de su dolor.

#### Crujidos y rigidez

Tal vez oiga chasquidos, crujidos o “tronidos” cuando mueve el hombro, sobre todo al levantar algo pesado.

## Conozca sus opciones de tratamiento

### Dos tipos de tratamiento

Existen dos tipos de tratamientos para su desgarro del manguito de los rotadores. Los pacientes mejoran con estos dos tipos de tratamientos.

- Tratamientos no quirúrgicos (vea abajo). Incluyen terapia física (fisioterapia) y otros tratamientos. A menudo estos tratamientos se utilizan primero, antes de considerar la cirugía.
- Tratamientos quirúrgicos (vea la página 7). Se utilizan diferentes tipos de cirugía. Toda cirugía implica riesgos específicos.

Su médico o personal de atención médica puede aconsejarle uno o ambos tipos de tratamientos para el desgarro de su manguito de los rotadores. Ese consejo dependerá del tipo y el tamaño de su lesión.

El grado de daño del tendón de su manguito de los rotadores ayudará a sus médicos a decidir qué tratamientos puede necesitar y cuánto tiempo llevarán.

### Tratamiento sin cirugía para el desgarro del manguito de los rotadores

El desgarro del manguito de los rotadores se trata sin cirugía de estas maneras:

- Con terapia física u ocupacional. Un terapeuta experto le ayuda con una variedad de ejercicios y estiramientos para fortalecer los músculos del hombro.
- Con medicamentos orales. Estos medicamentos pueden ser acetaminofén o “medicamentos antiinflamatorios no esteroideos” (conocidos también por la sigla AINE [o en inglés, NSAID]), como el ibuprofén o el naproxén.
- Con un esteroide en pastillas o inyecciones.

#### ¿Qué tratamiento debo escoger?

Se ha demostrado que muchos de estos tratamientos sin cirugía reducen el dolor, la debilidad y mejoran el movimiento del brazo. Sin embargo, no hay mucha información sobre qué tipo de tratamiento sea mejor que el otro.

Para ayudarle, su médico o personal de atención médica puede utilizar varios de estos tratamientos al mismo tiempo.

Tampoco existe suficiente investigación para saber si el movimiento del manguito de los rotadores mejora más con estos tratamientos que con la cirugía.

#### Su participación en el tratamiento

Usted tiene una responsabilidad importante en su recuperación. Siga las instrucciones de su médico u otro personal de atención médica. Cumpla con sus citas para la terapia y haga sus ejercicios en casa. Su médico le dirá qué puede esperar durante el tratamiento y cuándo debe empezar a sentirse mejor.

### Reparación del desgarro del manguito de los rotadores con cirugía

#### ¿Cuánto tiempo debo esperar antes de elegir la cirugía?

Los estudios no ofrecen suficiente información para responder esta pregunta. Su médico o personal de atención médica puede evaluar con usted sus opciones, de acuerdo con el tipo y tamaño de su desgarro y el tiempo que ha tenido la lesión. La terapia física puede bastar para reducir el dolor y la debilidad, o bien la cirugía puede ser una mejor opción de tratamiento. En algunos casos se utiliza la cirugía cuando la terapia física no reduce los síntomas.

#### ¿Cómo se repara el manguito de los rotadores en la cirugía?

En la mayoría de los casos, un cirujano aplica puntos de sutura para unir entre sí los bordes rasgados del músculo o tendón o para volver a conectar el tendón a la bola del húmero. Es lo que se llama “reparación del manguito de los rotadores”.

Además, su médico puede considerar otros dos tratamientos quirúrgicos:

- Retiro de fragmentos sueltos de tendón o de hueso o cartílago dañados que se hayan alojado en la articulación. Es lo que se llama “desbridación”.
- Retiro de parte del hueso debajo de la escápula o parte del tejido (ligamentos) entre los huesos de la articulación del hombro para que el tendón tenga más espacio y el brazo pueda moverse libremente. A esto se le llama “acromioplastia”.

#### Tres tipos de cirugía

- Cirugía artroscópica: El cirujano hace unas aberturas (cortes) muy pequeñas en los músculos del hombro y repara el desgarro por medio de un aparato llamado “artroscopio” (un tubo pequeño conectado a una cámara fotográfica y a instrumentos quirúrgicos minúsculos).
- Cirugía abierta: El cirujano hace una abertura más grande en los músculos del hombro y repara el desgarro con instrumentos quirúrgicos comunes.
- Cirugía miniabierta: El cirujano usa un artroscopio para la primera parte de la operación y luego hace una abertura lo suficientemente grande para usar otros instrumentos quirúrgicos para la reparación. La abertura no tiene que ser tan grande ni afectar tanto el músculo como en la cirugía abierta.

#### ¿Qué tipo de cirugía debo escoger?

Las investigaciones indican que:

- No hay diferencia entre los tipos de cirugía abierta, miniabierta y artroscópica para mejorar la función del hombro. Su utilidad es más o menos la misma. Sin embargo, la cirugía artroscópica por lo general requiere menos tiempo de recuperación.
- Algunos estudios encontraron que:
  □ Algunos pacientes que se sometieron a la cirugía miniabierta volvieron al trabajo o a los deportes aproximadamente 1 mes antes que los sometidos a cirugía abierta.
  □ Algunos pacientes que se sometieron a la reparación con cirugía abierta mostraron una mayor mejoría de la función del hombro que los tratados con desbridación artroscópica (retiro de fragmentos sueltos de tendón, hueso o cartílago alojados en la articulación) sin reparación del desgarro.
  □ Los resultados en los pacientes sometidos a cirugía artroscópica, con o sin acromioplastia (aumento del espacio en la articulación mediante retiro de parte del hueso o tejido), fueron casi iguales.

#### ¿Es segura la cirugía?

Toda cirugía conlleva cierto riesgo. Usted y su médico pueden identificar los riesgos que podrían haber para usted, tomando en cuenta su salud general. La cirugía del manguito de los rotadores es segura en la mayoría de las personas. Los problemas más comunes son la infección y la reaparición del desgarro.

#### ¿Qué tipo de tratamiento debo recibir después de la operación?

Si bien la mayoría de los médicos coinciden en que usted debe tener terapia de rehabilitación después de la cirugía, no hay evidencia suficiente para asegurar qué tipo es la mejor. Hable con su médico o personal de atención médica sobre el tipo de terapia de rehabilitación que más le conviene.

### Para ayudarle a decidir

#### Pregunte a su médico

1. Tomando en cuenta, ¿qué beneficios y daños con tratamientos no quirúrgicos o quirúrgicos debo considerar?
2. Si necesito operarme, considerando mi desgarro y mis otras condiciones médicas, ¿que tipo de cirugía (abierta, miniabierta o artroscópica) cree usted que sea mejor para mí?
3. ¿Qué tipo de tratamiento necesitaré después de la operación?
4. ¿Cuánto tiempo cree que tardaré en volver a mis actividades después del tratamiento?
5. ¿Estos tratamientos ayudarán a mi manguito de los rotadores por muchos años?
6. ¿Cuándo puedo esperar que disminuyan mi dolor y otros síntomas?

Otras preguntas para su médico:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva del informe Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears (Comparación de la efectividad de los tratamientos quirúrgicos y no quirúrgicos de los desgarros del manguito de los rotadores). Fue producida por el University of Alberta Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Alberta) mediante el financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por sus siglas en inglés). Para obtener una copia del informe o información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite http://www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol/. Se obtuvo información adicional de la página web Medline-Plus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Esta guía abreviada fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Universidad de Medicina de Baylor) en Houston, TX.