# Ablación con radiofrecuencia para tratar la fibrilación auricular

Guía para adultos

La fibrilación auricular (llamada también A-fib) es el problema más común del ritmo cardiaco. La probabilidad de tener A-fib aumenta con la edad. Menos de 3 de cada 1,000 personas menores de 65 años padecen de A-fib. Sin embargo, 90 de cada 1,000 personas padecen de A-fib llegados los 80 años.

La A-fib hace que el corazón lata rápidamente y puede causar síntomas, como palpitaciones, falta de aire y poca energía. La A-fib también aumenta el riesgo de sufrir un derrame.

## Hechos resumidos

- La fibrilación auricular (A-fib, como se conoce en inglés) puede tratarse de varias formas. Un tipo de tratamiento consiste en restablecer el ritmo normal del corazón.
- La ablación con radiofrecuencia (RFA, por sus siglas en inglés) es un procedimiento que se realiza para restablecer el ritmo normal del corazón.
- Durante la RFA, un alambre fino aplica calor para reparar las zonas problema que causan latidos del corazón anormales.
- Los medicamentos también pueden usarse para restablecer el ritmo normal del corazón.
- En las personas que ya han probado con medicamentos para el ritmo del corazón, la RFA es mejor para restablecer el ritmo normal del corazón que volver a intentar con estos medicamentos.
- Muy pocas veces la RFA origina problemas graves. De cada 100 personas que se tratan con RFA, unas 2 llegarán a tener un derrame o sangrado alrededor del corazón.

## ¿Qué cubre esta guía?

En esta guía se explica un procedimiento para las personas con A-fib que puede restablecer el ritmo normal del corazón. El procedimiento se llama ablación con radiofrecuencia (RFA, por sus siglas en inglés). “Ablación” significa eliminación de las zonas problema. Durante la RFA, los médicos hacen pasar un alambre muy fino por una vena hasta el corazón. Luego se aplica calor por medio del alambre a las zonas problema. El calor destruye una porción pequeña de tejido y detiene los latidos del corazón anormales.

La información de esta guía proviene de una revisión, financiada por el gobierno, de la investigación que compara la RFA con los medicamentos para el ritmo cardiaco. Los médicos pueden utilizar cada uno de estos tratamientos para tratar de restablecer el ritmo normal del corazón.

## ¿Qué no cubre esta guía?

Esta guía no cubre todos los tratamientos para la A-fib. No comenta la investigación sobre:

- Medicamentos para prevenir derrames, como la warfarina (Coumadin®).
- Medicamentos para retrasar el latido del corazón (como el metoprolol, el diltiazem y la digoxina).
- Otras formas de restablecer el ritmo normal del corazón, como la cardioversión eléctrica (que aplica una descarga eléctrica al corazón), los marcapasos o la cirugía a corazón abierto.
- Otros tipos de ablación que no usan calor, como la crioablación (tratamiento de congelación).

## El corazón

### Las cámaras del corazón

El corazón consta de cuatro “cámaras” o cavidades. La aurícula derecha y la aurícula izquierda son las cámaras superiores. Las cámaras superiores retienen la sangre antes de que entre en las cámaras inferiores. Los ventrículos derecho e izquierdo son las cámaras inferiores. Los ventrículos bombean sangre fuera del corazón a los pulmones y al resto del cuerpo.

### El sistema eléctrico natural del corazón

La imagen que aparece muestra el sistema eléctrico natural del corazón. Los latidos del corazón (contracciones) se controlan por medio de señales eléctricas. Cada señal se inicia en el nódulo sinusal (SA node, en inglés), situado en la aurícula derecha. La señal eléctrica viaja a través de las aurículas derecha e izquierda en camino hacia el nódulo auriculoventricular (AV node, en inglés). El nódulo AV envía la señal a los ventrículos. Esto hace que los ventrículos se contraigan y bombeen sangre hacia afuera del corazón. Los dos lados del corazón bombean al mismo tiempo. Normalmente, las señales eléctricas del nódulo SA hacen que el corazón lata entre 60 y 100 veces por minuto.

## La A-fib

### ¿Qué causa la A-fib?

La A-fib se produce por un problema en el sistema eléctrico del corazón. En la A-fib, la mayoría de las señales eléctricas se inician en lugares distintos al nódulo sinusal. Esto ocasiona que las aurículas derecha e izquierda latan muy rápido y a un ritmo irregular. Este latido irregular se llama fibrilación. En algunas personas, la A-fib es constante; en otras, aparece y desaparece.

La A-fib es más común en las personas mayores de 65 años. Las personas de más edad tienden más a presentar condiciones médicas que aumentan el riesgo de que ocurra A-fib, como las enfermedades del corazón y la presión arterial alta.

### ¿Por qué se debe tratar la A-fib?

En la A-fib, el ritmo del corazón es mucho más rápido que lo normal. Eso puede causar síntomas como palpitaciones, falta de aire y poca energía. Algunas personas no presentan ningún tipo de síntomas.

Sin embargo, la A-fib puede causar problemas aun cuando no haya síntomas. La A-fib aumenta la posibilidad de que ocurra un derrame. En la A-fib, las aurículas derecha e izquierda no se contraen de manera uniforme. Eso significa que la sangre no se descarga totalmente en los ventrículos. Cuando eso ocurre, pueden formarse coágulos en la aurícula. Los coágulos pueden desprenderse, llegar al cerebro y causar un derrame.

## Tratamientos para la A-fib

Algunas personas con A-fib toman medicamentos que sólo ayudan a evitar los coágulos de sangre y derrames. Por lo general se trata de warfarina (Coumadin®) o aspirina.

Los otros tratamientos de la A-fib pertenecen a dos grupos diferentes. Un grupo disminuye la frecuencia cardiaca (heart rate, en inglés) y el otro restablece el ritmo normal del corazón.

Por lo general, los médicos recomiendan primero tratar de controlar la frecuencia cardiaca. En muchas personas, todo lo que se necesita es un medicamento que controle la frecuencia cardiaca.

Si la persona no puede tomar estos medicamentos, o si no se alivian los síntomas de la A-fib, los médicos pueden probar otra estrategia. En su lugar, pueden tratar de restablecer el ritmo normal del corazón.

Los medicamentos para el ritmo cardiaco y la RFA son tratamientos que se utilizan para restablecer el ritmo normal del corazón. Al normalizar el ritmo del corazón se logra que las cámaras superiores e inferiores del corazón trabajen en coordinación.

### Medicamentos para el ritmo del corazón

Se usan muchos medicamentos distintos para restablecer el ritmo normal del corazón. Los medicamentos que aparecen abajo se han comparado con la RFA en estudios de investigación.

- Amiodarona (Pacerone® y Cordarone®)
- Flecainida (Tambocor®)
- Propafenona (Rythmol®)
- Sotalol (Betapace®)
- Disopiramida (Norpace®)

Estos medicamentos pueden ayudar a restablecer el ritmo normal del corazón, pero pueden tener efectos secundarios graves. Pueden causar nuevos problemas en el ritmo del corazón. También pueden hacer que el corazón lata demasiado despacio. Hay muchos otros efectos secundarios posibles.

### ¿Cómo se hace la RFA?

La RFA es otro modo de restablecer el ritmo normal del corazón. Detiene las señales eléctricas que vienen de otros lugares que no son el nódulo SA. En la RFA, se hace pasar un alambre muy fino por una vena del brazo o la pierna hasta el corazón. Se usa un alambre para identificar las zonas problema en el sistema eléctrico del corazón. Luego se envía calor por otro alambre. El calor destruye un poco de tejido en las zonas problema y detiene los latidos del corazón anormales. Una vez reparadas todas las zonas problema, se extraen los alambres.

El procedimiento de RFA puede durar 3 horas o más. El médico mueve cuidadosamente los alambres entre las cámaras del corazón. Cuando termina el procedimiento, la mayoría de las personas no sienten mucho dolor. Usted deberá permanecer acostado algunas horas, pero puede salir del hospital el mismo día. Algunas personas necesitan quedarse en el hospital toda la noche o más. En la mayoría de los casos, las personas se someten a RFA solamente una vez.

## Beneficios de la RFA

Las personas que han intentado con medicamentos para el ritmo cardiaco y aún tienen A-fib, la RFA es más efectiva para restablecer el ritmo normal del corazón que intentar con medicamentos una segunda ocasión.

La investigación demuestra que después de 1 año:

- 74 de 100 personas que se someten a RFA se liberan de la A-fib.
- 20 de 100 personas que prueban por segunda vez un medicamento para el ritmo cardiaco se liberan de la A-fib.

Desconocemos cómo se comparan los medicamentos para el ritmo cardiaco y la RFA después de un largo tiempo. La mayoría de las investigaciones no han durado más de 1 año.

La RFA es igualmente útil en hombres y en mujeres y en personas de edades diferentes. Tampoco el tiempo que la persona ha padecido de A-fib afecta la eficacia de la RFA.

### ¿Qué se desconoce todavía?

Aún no se ha realizado la investigación suficiente para responder algunas de las preguntas que probablemente tenga sobre la RFA.

- No se sabe con certeza si la RFA o los medicamentos para el ritmo cardiaco son mejores para prevenir derrames, insuficiencia cardiaca congestiva o muerte en el futuro.
- No se sabe con certeza si la RFA es mejor que los medicamentos para el ritmo cardiaco en personas que nunca han intentado tratarse con estos medicamentos.
- No se sabe con certeza si la RFA o los medicamentos para el ritmo cardiaco permiten más a menudo que la persona deje de tomar medicamentos que previenen los coágulos de sangre y derrames.
- No se sabe con certeza cuál de los dos tratamientos (RFA o medicamentos para el ritmo cardiaco) hace que la gente se sienta mejor en general.

## Riesgos de la RFA

Son problemas posibles de la RFA el sangrado o el dolor en el punto de introducción de los alambres. Puede haber problemas más graves, pero son poco comunes.

### Derrames

La RFA puede causar problemas que ocasionen un derrame.

- Aproximadamente 1 de cada 100 personas que se someten a la RFA tiene un derrame por el procedimiento.

### Sangrado alrededor del corazón

La RFA puede causar problemas de sangrado alrededor del corazón. A veces la RFA produce un escape en la pared del corazón. Si entra mucha sangre en la bolsa que envuelve al corazón, puede hacer presión en él. Es lo que se llama taponamiento cardiaco. Si eso ocurre, será necesario retirar la sangre de la bolsa alrededor del corazón. Por lo general, para hacer esto se introduce una aguja por el pecho. A veces se necesita cirugía.

- El taponamiento cardiaco ocurre en aproximadamente 1 de cada 100 personas que se hacen la RFA.

A veces el problema de sangrado es más grave. En casos raros, puede formarse un orificio entre el corazón y el esófago después de la RFA. En esa situación, escapa sangre del corazón hacia el esófago. Ha sucedido solamente en pocas personas sometidas a RFA. Cuando ocurre, puede causar hemorragia grave y la muerte.

### Estrechamiento de las venas pulmonares

Las venas pulmonares llevan sangre de los pulmones al corazón. La RFA destruye las zonas problema cerca de las venas pulmonares, para corregir la A-fib. Las cicatrices que se forman después pueden hacer que las venas se estrechen.

- Ese estrechamiento de las venas pulmonares ocurre en menos de 1 de cada 100 personas que se hacen la RFA.
- Por lo general, el estrechamiento de las venas pulmonares no causa síntomas y no necesita tratamiento.

## Hable con su médico sobre la A-fib y la RFA

La investigación no indica con certeza qué personas tienen una mayor probabilidad de beneficiarse con la RFA. Pregunte a su médico o enfermera qué tal le podría funcionar a usted. Tal vez quiera hacer preguntas como éstas:

- ¿Bastará con sólo tomar medicamentos para reducir mi frecuencia cardiaca?
- ¿Bastará con sólo tomar medicamentos para cambiar el ritmo de mi corazón?
- ¿La RFA aliviará mis síntomas de A-fib?
- Si la RFA corrige la A-fib, ¿podré dejar de tomar medicamentos que evitan coágulos de sangre y derrames, como la warfarina (Coumadin^®^)?
- ¿Qué tipo de seguimiento necesitaré después de la RFA?

## ¿Dónde puede obtener más información?

Visite www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Pulse en la guías para pacientes y consumidores si desea imprimir una copia y aprender sobre otras condiciones.

Si desea ejemplares impresos gratuitos de esta guía, llame al 800-358-9295. Pida a la AHRQ Publications Clearinghouse la Publicación AHRQ Número 09(10)-EHC015-B.

Para aprender más sobre la fibrilación auricular, visite www.nhlbi.nih.gov/health/dci/Diseases/af/af_what.html (disponible solamente en inglés).

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 120 informes de investigación. La revisión se titula Comparative Effectiveness of Radiofrequency Catheter Ablation for Atrial Fibrillation (Comparación de la efectividad de ablación con radiofrecuencia para tratar la fibrilación auricular) (2009) y fue escrita por el Tufts Medical Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro Médico de Tufts).

## Related Content

Research Review

Clinician Guide

Consumer Guide