# Opciones para tratar el síndrome de las piernas inquietas

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es para usted si

- Su médico^*^ le ha dicho que usted tiene el síndrome de las piernas inquietas (RLS, por su sigla en inglés), llamado también enfermedad de Willis-Ekbom, y usted desea saber lo que han encontrado los investigadores sobre las opciones de tratamiento.
- Usted tiene 18 años o más. Esta información proviene de investigaciones realizadas en adultos.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Qué es el RLS
- Opciones de tratamiento para el RLS
- Qué han encontrado los investigadores sobre los tratamientos para el RLS

Este resumen puede ayudarle a hablar con su médico sobre cuál tratamiento podría ser mejor para usted.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del Gobierno federal, revisaron 53 estudios acerca de los tratamientos para el RLS, publicados hasta junio de 2012. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en: www.effectivehealthcare.ahrq.gov/restless-legs.cfm (disponible sólo en inglés).

Nota: Las personas incluidas en las investigaciones para este resumen tenían RLS de moderado a grave y de larga duración. En las personas con RLS moderado a grave, el RLS afecta su capacidad para realizar las actividades diarias o para dormir. Esta información puede no ser relevante para las personas con RLS leve.

Las investigaciones para este resumen no incluyeron a mujeres embarazadas, personas tratadas con diálisis por enfermedad renal ni personas de edad avanzada con otros problemas de salud. Estos grupos tienen mayor riesgo de desarrollar RLS y probablemente también de tener efectos secundarios por los medicamentos para el RLS.

Los estudios incluidos en la investigación para este resumen son “ensayos controlados aleatorizados”. Este tipo de estudio se considera como investigación de alta calidad. No todos los tratamientos para el RLS se han estudiado en un ensayo controlado aleatorizado.

## Conozca su condición

### ¿Qué es el síndrome de las piernas inquietas?

El síndrome de las piernas inquietas (RLS) es un trastorno del sistema nervioso (el sistema formado por el cerebro, la médula espinal y los nervios).

Para que un médico le diagnostique RLS, usted debe tener lo siguiente:

- Sentir un impulso muy fuerte de mover las piernas. A menudo, el RLS también le causa sensaciones desagradables o dolorosas en las piernas.
  - Puede sentir picazón o cosquilleo en las piernas o sentir hormigueo, ardor, tirantez, dolorimiento o dolor punzante.
  - Sentir jalones o espamos en las piernas.
  - Estas sensaciones pueden tenerse también en otras partes del cuerpo, como los brazos.
- Los síntomas empeoran al sentarse o al acostarse.
- Los síntomas se calman o desaparecen cuando usted se mueve, pero reaparecen cuando vuelve a sentarse o acostarse.
- Los síntomas son más intensos por la tarde o la noche.
  - Esto puede hacer difícil conciliar el sueño o mantenerse dormido.

Los síntomas del RLS pueden variar de leves a graves. El RLS puede hacer que se sienta cansado durante el día y puede afectar sus actividades diarias. Puede también afectar su bienestar emocional y ocasionar ansiedad y depresión. Se puede tener RLS a cualquier edad, pero los síntomas pueden empeorar conforme aumenta la edad de la persona.

En Estados Unidos, hasta 7 de cada 100 personas tienen RLS.

### ¿Que causa el RLS?

Los médicos no saben exactamente qué causa el RLS. Puede pasar de una generación a otra en una misma familia. Varias cosas pueden desencadenar o empeorar los síntomas del RLS; por ejemplo:

- Pasar mucho tiempo sentado (como en un auto, un avión o en un teatro)
- Algunas condiciones, como la deficiencia de hierro, la insuficiencia renal, la diabetes, problemas de los nervios o el embarazo
- El uso de ciertos medicamentos, como algunos antihistamínicos (medicamentos para controlar la alergia) o los antidepresivos
- Consumo de alcohol o cafeína
- Fumar o usar otros productos de tabaco
- No dormir lo suficiente

## Conozca sus opciones

### ¿Cómo se trata el RLS?

Hasta hoy, no hay cura para el RLS. Sin embargo, hay cambios en el estilo de vida o tratamientos con o sin medicamentos que pueden aliviar los síntomas y ayudarle a dormir mejor. A continuación, se ofrecen detalles sobre cada uno de estos tipos de tratamiento y lo que los investigadores han encontrado al respecto.

#### Cambios en el estilo de vida

Se han propuesto varios cambios en el estilo de vida para aliviar los síntomas del RLS. A continuación, se ofrecen algunos ejemplos:

- Limitar o evitar la cafeína, el alcohol y el tabaco.
- Cambiar o dejar de utilizar cualquier medicamento que pueda empeorar su RLS (por ejemplo algunos antihistamínicos y antidepresivos).
  - Nunca deje de tomar un medicamento sin antes preguntar a su médico.
- Haga ejercicio algunas veces por semana (como en una caminadora o con ejercicios que fortalezcan la parte baja del cuerpo).
  - Sin embargo, demasiado ejercicio puede empeorar los síntomas de RLS. Hable con su médico sobre la cantidad de ejercicio que es apropiado para usted.
- Procure irse a acostar aproximadamente a la misma hora todas las noches y levantarse a la misma hora cada mañana.

### ¿Qué dicen las investigaciones sobre los cambios en el estilo de vida para tratar el RLS?

Los investigadores observaron que:

- El ejercicio (en la caminadora y con rutinas para fortalecer la parte baja del cuerpo), tres veces por semana, pueden ayudar a aliviar los síntomas del RLS, pero se necesita más investigación para saberlo con certeza.
- No existe suficiente investigación para saber si otros cambios en el estilo de vida son eficaces para tratar el RLS.

#### Tratamientos sin medicamentos

Se han probado varios métodos sin medicamentos para tratar el RLS, entre ellos los siguientes:

- Baños calientes o fríos
- Masaje
- Medias de compresión: medias hechas de material elástico fuerte, que comprimen suavemente las piernas
- Dispositivos de compresión neumática: cubiertas para las piernas que se inflan y desinflan con una bomba de aire, para comprimir las piernas durante la noche
- Terapia con luz del infrarrojo cercano: tratamientos con un aparato que utiliza luz del infrarrojo cercano (la parte roja del espectro luminoso) para ayudar a aumentar la circulación en sus piernas

### ¿Qué dicen las investigaciones sobre los tratamientos sin medicamentos para el RLS?

Los investigadores observaron que:

- Los dispositivos de compresión neumática son eficaces para aliviar los síntomas del RLS.
- La terapia con luz del infrarrojo cercano puede ayudar a aliviar los síntomas de RLS, pero se necesita más investigación para saberlo con certeza.
- No existe investigación suficiente (y en algunos casos ninguna) para conocer la eficacia de otros tratamientos sin medicamentos para tratar el RLS.

#### Medicamentos

Se han utilizado varios tipos de medicamentos para tratar el RLS, entre ellos los siguientes:

- Agonistas de la dopamina: Estos medicamentos actúan modificando el nivel de una sustancia llamada dopamina en el cerebro. Los agonistas de la dopamina que se estudiaron en las investigaciones para este resumen son:
  - Pramipexol (Mirapex^®^)^*^
  - Ropinirol (Requip^®^)^*^
  - Parche para piel de Rigotina (Neupro^®^)^*^
- Medicamentos anticonvulsivos: Estos medicamentos suelen utilizarse parar detener las convulsiones y el dolor de nervios. No es necesario que tenga convulsiones para que pueda tomar este tipo de medicamentos. Los medicamentos anticonvulsivos que se estudiaron en las investigaciones para este resumen son:
  - Pregabalina (Lyrica^®^)
  - Gabapentina (Neurontin^®^)
  - Enacarbilo de gabapentina (Horizant^®^)^*^
- Hierro: El hierro suele administrarse a las personas que tienen muy poco hierro en el cuerpo. El hierro puede tomarse en pastillas o administrarse por vía intravenosa (IV) en el brazo.
  - Tomar demasiado hierro puede ser peligroso, de modo que es importante que hable con su médico antes de tomar hierro.

Nota: Algunas personas han tomado los medicamentos siguientes para tratar el RLS. No existe suficiente investigación para saber si son eficaces o si son seguros para tratar el RLS.

- Opioides (analgésicos potentes que pueden llegar a ser adictivos), como la codeína, la hidrocodona (Vicodin^®^, Lortab^®^), la morfina (DepoDur^®^) o la oxicodona (Tylox^®^, Percodan^®^, Oxycontin^®^)
- Sedantes (medicamentos que relajan sus músculos y ayudan a dormir), como clonazepam (Klonopin^®^), oxazepam (Serax^®^) o temazepam (Restoril^®^)

### ¿Qué dicen las investigaciones sobre los medicamentos para tratar el RLS?

Los investigadores observaron que:

- Los agonistas de la dopamina son eficaces para aliviar los síntomas del RLS, mejorar la calidad de vida y mejorar el sueño.
- El medicamento anticonvulsivo encarbilo de gabapentina (Horizant^®^) es eficaz para mejorar el sueño. Es probable que también mejore la calidad de vida, pero se necesita más investigación para saberlo con certeza.
- El medicamento anticonvulsivo pregabalina (Lyrica^®^) es eficaz para aliviar los síntomas del RLS. Al parecer, no mejora la calidad de vida, pero se necesita más investigación para saberlo con certeza.
- No existe suficiente investigación para saber qué tan eficaz es el medicamento anticonvulsivo gabapentina (Neurontin^®^) para tratar el RLS.
- El hierro intravenoso (IV) es eficaz para aliviar los síntomas del RLS y mejora la calidad de vida. También puede mejorar el sueño, pero se necesita más investigación para saberlo con certeza.
- Las pastillas de hierro pueden ayudar a aliviar los síntomas del RLS en las personas que tienen muy poco hierro en el cuerpo, pero se necesita más investigación para saberlo con certeza.

### ¿Cuáles son los efectos secundarios posibles de los medicamentos para tratar el RLS?

Medicamentos | Posibles efectos secundarios | Más información sobre efectos secundarios posibles
Agonistas de la dopamina^*^
- Pramipexol (Mirapex^®^); - Ropinirol (Requip^®^); - Parche para piel de Rigotina (Neupro^®^) | - Náusea y vómito; - Sueño excesivo; - Cansancio; - Dolor de cabeza; - Alucinaciones (ver u oír cosas que no existen); - Impulsos intensos (como apostar dinero o tener relaciones sexuales) | - En algunas personas, los agonistas de la dopamina pueden hacer que los síntomas del RLS comiencen más temprano en el día, empeoren o se extiendan a otras partes del cuerpo, como los brazos. A esto se le llama “exacerbación”.; - El parche para la piel de Rigotina (Neupro^®^) puede también causar enrojecimiento, hinchazón y comezón en la parte de la piel donde se pone el parche.
Medicamentos anticonvulsivos^*^
- Enacarbilo de gabapentina (Horizant^®^); - Gabapentina (Neurontin^®^); - Pregabalina (Lyrica^®^) | - Mareos; - Sueño excesivo; - Cansancio; - Hinchazón de los tobillos o los pies; - Dificultad para pensar o concentrarse; - Dificultad para mantener el equilibrio; - Mayor riesgo de pensamientos suicidas | - El medicamento anticonvulsivo pregabalina (Lyrica^®^) también puede causar los efectos secundarios siguientes. Si usted tiene alguno de estos efectos secundarios, llame inmediatamente a su médico.; - Boca seca; - Visión borrosa; - Aumento de peso; - Dificultad para concentrarse; - Inflamación de la garganta, la cabeza y el cuello; - Una reacción alérgica (urticaria, falta de aire o sibilancias)
Hierro^†^
- Pastillas de hierro; - Hierro intravenoso (IV) | - Náusea y vómito; - Estreñimiento; - Diarrea; - Malestar estomacal; - Heces de color oscuro | - Tomar demasiado hierro puede ocasionar intoxicación por hierro. Es importante que hable con su médico antes de tomar hierro.

* Los efectos secundarios posibles de la lista provienen de la FDA.

† El hierro es un suplemento dietético. A diferencia de los medicamentos de venta sin receta, los suplementos alimenticios no tienen que ser aprobados por la FDA. Los efectos secundarios posibles del hierro citados aquí provienen de la página web de la National Institutes of Health Office of Dietary Supplements (Oficina de Suplementos Alimenticios de los Institutos Nacionales de la Salud), disponible en inglés en http://ods.od.nih.gov/factsheets/Iron-HealthProfessional/.

Nota: Si está embarazada, hable con su médico antes de tomar un medicamento agonista de la dopamina o un anticonvulsivo. Estos medicamentos pueden dañar al feto.

Los medicamentos agonistas de la dopamina y los anticonvulsivos pueden causar sueño excesivo. Pregunte a su médico si es seguro conducir vehículos mientras toma su medicamento para el RLS.

### ¿Cuánto cuestan los medicamentos para el RLS?

Los costos que tengan para usted estos medicamentos dependerán de su seguro médico, la dosis (cantidad) que necesite, si el medicamento existe en forma genérica y de la farmacia donde compre el medicamento.

- Los agonistas de la dopamina pramipexol (Mirapex^®^) y ropinirol (Requip^®^) y el medicamento anticonvulsivo gabapentina (Neurontin^®^) existen todos en forma genérica.
- Los precios promedio de mayoreo de los medicamentos agonistas de la dopamina y los anticonvulsivos para tratar el RLS varían de $80 a $185^*^ por mes.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar muchos factores al decidir qué tratamiento del RLS puede ser mejor para usted. Tal vez usted y su médico quieran hablar sobre:

- Qué tan intensos son sus síntomas de RLS y qué tanto están afectando su sueño o sus actividades diarias
- Los beneficios y efectos secundarios posibles de cada tratamiento
- Qué tratamiento se adapta mejor a sus preferencias y estilo de vida (algunas personas desearán intentar cambios en su estilo de vida, como hacer ejercicio, mientras que otras preferirán tomar un medicamento)
- El costo de cada tratamiento.

### Pregunte a su médico

- ¿Qué cambios en mi estilo de vida podrían aliviar mi RLS?
- ¿Estoy tomando medicamentos que pueden empeorar mi RLS?
- ¿Un tratamiento sin medicamentos mejoraría mi RLS?
- ¿Un medicamento mejoraría mi RLS? En tal caso, ¿qué tipo de medicamento sería el mejor para mí?
- ¿Afectará el medicamento a otros que tomo?
- Si tomo un agonista de la dopamina, ¿qué probabilidad hay de que tenga una exacerbación (de que los síntomas comiencen más temprano en el día, empeoren o se extiendan a otras partes del cuerpo)?
- ¿Cómo sabré si mi medicamento está causando una exacerbación?
- ¿Hay algo que pueda hacer para tratar de evitar la exacerbación?
- ¿Hay algo más que pueda hacer para ayudar a aliviar mis síntomas de RLS y ayudarme a dormir?

## Fuente

La información de este resumen proviene del informe Treatment for Restless Legs Syndrome (Tratamiento del síndrome de piernas inquietas), de noviembre de 2012. Fue producido por el Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Minnesota), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program, visite www.effectivehealthcare.ahrq.gov/restless-legs.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Este servicio está disponible en español en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas que tienen el síndrome de las piernas inquietas.

Esta guía fue traducida de la publicación en inglés titulada Options for Treating Restless Legs Syndrome: A Review of the Research for Adults.

* En este resumen, el término “médico” se refiere al profesional de la atención médica que lo atiende, como puede ser su médico, enfermera o asistente médico.

* La U.S. Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA por su sigla en inglés) ha aprobado estos medicamentos para tratar el RLS de moderado a grave.

* Los precios son los precios promedio de mayoreo según el REDBOOK Online^®^ redondeados a los $5 más cercanos. Los precios de mayoreo son los precios que pagan las farmacias.