# Tratamientos para la estenosis de la arteria renal

Guía para el consumidor

## Hechos resumidos

- Se llama estenosis de la arteria renal (RAS, por sus siglas en inglés) al estrechamiento en uno o en ambos vasos sanguíneos de los riñones. RAS puede hacer que la presión arterial sea difícil de controlar.
- A la fecha, no se sabe si la mejor manera de tratar RAS consista en tomar pastillas para disminuir la presión arterial o someterse a angioplastia, un procedimiento en el que se despeja la parte obstruida.
- Tanto los medicamentos como la angioplastia disminuyen la presión arterial en las personas que tienen RAS.
- Entre las personas que se someten a angioplastia para tratar RAS, algunas pueden dejar de tomar las pastillas para disminuir la presión arterial. No obstante, la mayoría debe seguir tomando las pastillas para la presión arterial incluso después de la angioplastia.
- A largo plazo, no hay diferencia en la función renal entre las personas que se someten a angioplastia y las que sólo toman pastillas para tratar RAS.

## ¿Qué cubre esta guía?

Esta guía le ayudará a hablar con su médico o enfermera sobre los tratamientos para la estenosis de la arteria renal.

Se llama estenosis de la arteria renal (RAS) al estrechamiento de uno o de ambos vasos sanguíneos (las arterias renales) que llevan la sangre a cada riñón. Los riñones ayudan a regular la presión de la sangre en el cuerpo. Cuando una arteria renal se estrecha, los riñones trabajan con más esfuerzo. RAS puede empeorar con el transcurso del tiempo. A menudo ocasiona aumento de la presión arterial y daño a los riñones.

La información de esta guía proviene de una revisión detallada, financiada por el gobierno, de informes de investigación sobre el tratamiento de RAS. Se tratan los siguientes temas en esta guía:

- Problemas de salud causados por RAS, como presión arterial alta y daño a los riñones.
- Dos tipos de tratamiento para RAS.

## ¿Qué no cubre esta guía?

- Quiénes deben someterse a pruebas para detectar RAS.
- La mejor prueba para saber si usted tiene RAS.
- Si los cambios en el estilo de vida ayudan a reducir RAS.
- Cirugía para corregir RAS.
- Un tipo poco frecuente de RAS, causado por displasia fibromuscular (las paredes de la arteria se vuelven más gruesas).

## Aprenda sobre la estenosis de la arteria renal

### ¿Cuáles son las causas de RAS?

- Casi siempre (9 de cada 10 casos), el estrechamiento es causado por la formación de placa. La placa es una acumulación de grasas, colesterol, y otros materiales.
- Con el tiempo, la placa acumulada causa obstrucción de las arterias renales. Este problema se denomina enfermedad aterosclerótica o endurecimiento de las arterias.

### ¿En quiénes ocurre RAS?

- El riesgo de presentar RAS es más alto en las personas de edad mayor, porque la cantidad de placa arterial va aumentando con el tiempo.
- RAS es frecuente en personas que tienen problemas de obstrucción de las arterias también en otras partes del cuerpo, como las piernas o el corazón.

### ¿Cómo sabe si tiene RAS?

- Por lo general no hay síntomas.
- Si su presión arterial alta es muy difícil de controlar, es probable que se deba a RAS. Es posible que su médico o enfermera decidan hacer estudios especiales para confirmarlo.

## Tratamientos para la estenosis de la arteria renal

### ¿Cuál es el mejor tratamiento para RAS?

Existen dos tipos de tratamiento para RAS. Uno consiste en tomar pastillas para disminuir la presión arterial y el otro en someterse a angioplastia. Algunas personas necesitan ambos métodos. A la fecha, no se sabe cuál es más eficaz.

### ¿Qué tratamientos disminuyen la presión arterial?

#### Medicamentos

Los medicamentos pueden disminuir la presión arterial y el colesterol. En general, esto significa tomar dos o más tipos de pastillas.

#### Angioplastia

La angioplastia se utiliza para despejar la arteria obstruida. El médico introduce un pequeño globo en la arteria renal y luego lo infla para abrir la parte obstruida. A veces, durante la angioplastia, se coloca un pequeño tubo metálico o férula (stent, como se conoce en inglés) que ayuda a mantener la arteria abierta.

- Es más probable que se logre controlar la presión arterial si la persona se somete a angioplastia y sigue tomando medicamentos para disminuir la presión arterial. Sin embargo, es posible que este mejor control se logre solamente en quienes la angioplastia se usó para tratar las obstrucciones en ambas arterias renales.
- Algunas personas que se han sometido a angioplastia para tratar RAS pueden dejar de tomar pastillas para disminuir la presión arterial. De cada 100 personas con RAS que se someten a angioplastia, entre 4 y 18 pueden dejar de tomarlas. Las demás deben seguir tomando sus medicamentos para la presión arterial.

### ¿Qué tratamientos favorecen más a los riñones?

A largo plazo, no existen diferencias en la función renal de las personas que se someten a angioplastia y las que sólo toman pastillas para la presión arterial para tratar RAS.

## ¿Cuándo se tendrá más información?

Un estudio de investigación que actualmente está en curso se propone averiguar cuál es el mejor tratamiento para RAS. Sus resultados se conocerán en el año 2010. El nombre de este estudio es Cardiovascular Outcomes in Renal Atherosclerotic Lesions (Resultados cardiovasculares en lesiones ateroscleróticas renales) o CORAL, por sus siglas en inglés. Está financiado por los Institutos Nacionales de Salud de Estados Unidos. Incluye dos grupos de personas con RAS. Un grupo se someterá a angioplastia con endoprótesis y luego seguirá tomando pastillas para controlar la presión arterial. El otro grupo tomará pastillas para controlar la presión arterial sin someterse a angioplastia.

En esta página Web encontrará más información sobre el estudio CORAL: www.coralclinicaltrial.org/public/index.html

## ¿Qué riesgos implican los tratamientos?

Todos los tratamientos pueden ocasionar efectos secundarios. Si está considerando algún tratamiento para RAS, pregunte a su médico o enfermera qué riesgo corre de tener alguno de estos efectos secundarios o complicaciones.

### Pastillas para disminuir la presión arterial

- Los medicamentos para disminuir la presión arterial pueden tener efectos secundarios como mareo, problemas sexuales, dolor de cabeza, y tos. Los efectos secundarios varían según el tipo de pastillas que se usen.

### Angioplastia

- La angioplastia, sola o complementada con endoprótesis, puede producir formación de moretones, sangrado, y más daño a los riñones. También es posible que las arterias vuelvan a cerrarse.
- Aproximadamente 1 de cada 100 personas que se someten a angioplastia para tratar RAS muere durante el mes siguiente al tratamiento. No hay datos que permitan comparar esa situación con la de las personas que se tratan RAS solamente con pastillas.

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía y materiales sobre la elección de tratamientos y medicamentos para otros trastornos de salud, visite esta página Web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm

Para obtener una copia gratuita, llame a:

AHRQ Publications Clearinghouse, (800) 358-9295

Pida la publicación de AHRQ número: 07(09)-EHC004-B

Si desea más información sobre la estenosis de la arteria renal, visite esta página Web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/ency/article/001273.htm

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 56 informes de investigación. La revisión se titula Comparative Effectiveness of Management Strategies for Renal Artery Stenosis – 2006 (Comparación de la efectividad en el manejo de estrategias para la estenosis de la arteria renal – 2006), y fue escrita por el Tufts New England Medical Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro Médico de Tufts en Nueva Inglaterra).

## Related Content

Research Review

Research Review (Update)

Clinician Guide

Consumer Guide