# Medicamentos para la artritis reumatoide

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, este resumen es para usted si

- Su médico le ha dicho que tiene artritis reumatoide (RA, por su sigla en inglés).
- Su médico le ha sugerido tomar uno o más de los siguientes medicamentos antirreumáticos modificadores de la enfermedad (DMARD, por su sigla en inglés) para tratar su RA:
  - Abatacept (Orencia^®^)
  - Adalimumab (Humira^®^)
  - Anakinra (Kineret^®^)
  - Certolizumab pegol (Cimzia^®^)
  - Etanercept (Enbrel^®^)
  - Golimumab (Simponi^®^)
  - Hidroxicloroquina (Plaquenil^®^)
  - Infliximab (Remicade^®^)
  - Leflunomida (Arava^®^)
  - Metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^)
  - Rituximab (Rituxan^®^)
  - Sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^)
  - Tocilizumab (Actemra^®^)
- Su médico le ha sugerido tomar un corticoesteroide junto con un DMARD, para tratar su RA:
  - Metilprednisolona (Depo Medrol^®^, Medrol^®^, Solu-Medrol^®^)
  - Prednisolona (Delta-Cortef^®^, Econopred^®^, Orapred^®^, Pediapred^®^, Prelone^®^)
  - Prednisona (Deltasone^®^, Liquidpred^®^, Sterapred^®^)
- Quiere saber qué dicen las investigaciones acerca de los beneficios y efectos secundarios de estos medicamentos.

### Este resumen no es para usted si

- Tiene un tipo de artritis que no es RA, como la osteoartritis.
- Su médico no le ha sugerido tomar un DMARD o corticoesteroides para tratar la RA.
- Tiene menos de 18 años de edad. Esta información proviene de investigación realizada en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen le informará sobre dos tipos de medicamentos que se usan para tratar la RA: los DMARD y corticoesteroides. Le explicará lo que han descubierto las investigaciones sobre la eficacia de los DMARD, cuando se toman solos o con corticoesteroides, para tratar la RA. También le dirá lo que dicen las investigaciones acerca de los beneficios y efectos secundarios de estos medicamentos. Usted puede usar este resumen para hablar con su médico y determinar si alguno de estos medicamentos puede ser apropiado para usted.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 211 estudios acerca de los medicamentos para la RA publicados entre enero de 1990 y enero de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/dmardsra.cfm (disponible solo en inglés).

## Conozca su condición

### ¿Que es la artritis reumatoide?

La artritis reumatoide (RA) es una enfermedad que causa dolor, hinchazón y rigidez en las articulaciones. En algunas personas, también puede causar daño o deformidad en las articulaciones.

- Aunque puede afectar cualquier articulación del cuerpo, la RA se encuentra con mayor frecuencia en las manos, las muñecas, los pies y las rodillas. Usualmente, si se encuentra en una mano, aparecerá también en la otra.
- En ocasiones, la RA puede causar problemas en otras partes del cuerpo distintas a las articulaciones, como el corazón, los pulmones, los ojos o la boca.
- La RA suele durar muchos años o incluso toda la vida. En algunas personas, la RA puede desaparecer con tratamiento después de unos meses o años. Sin embargo, es un suceso poco frecuente.
- Los síntomas de la RA (dolor, hinchazón, rigidez) pueden empeorar durante ciertos periodos (llamados “crisis”) y luego mejorar durante otros.

### ¿Qué causa la RA?

Se desconoce la causa de la RA, pero los investigadores piensan que la condición puede pasarse en las familias, de generación en generación. El dolor y los síntomas de la RA ocurren cuando su sistema inmunológico (el sistema corporal que le ayuda a defenderse de los microbios) ataca el revestimiento sano de sus articulaciones. Los médicos no saben con seguridad por qué el sistema inmunológico ataca las articulaciones en algunas personas.

### ¿Qué tan frecuente es la RA?

- La RA es menos común que otros tipos de artritis, como la osteoartritis.
- En Estados Unidos, más de 1 millón de personas padecen de RA.
- Las mujeres tienden más a padecer de RA que los hombres. Cerca de 7 de cada 10 personas con RA son mujeres.
- Aunque la RA puede ocurrir a cualquier edad, por lo general se desarrolla entre los 30 y 50 años de edad.

### ¿Cómo puede ayudar el tratamiento?

Aunque no hay cura para la RA, el tratamiento puede:

- Aliviar el dolor y la hinchazón
- Retardar o detener el daño a las articulaciones
- Ayudar a reducir el número de “crisis” con los síntomas (momentos en que empeora el dolor o la hinchazón)
- Mejorar su capacidad de realizar actividades diarias como bañarse, vestirse, hacer labores domesticas, extender los brazos y levantar objetos

### ¿Qué medicamentos se usan para tratar la RA?

La RA se trata con varios tipos distintos de medicamentos, incluidos:

- Analgésicos: Medicamentos sin receta, como aspirina, acetaminofén (Tylenol^®^), ibuprofeno (Advil^®^, Motrin^®^) o naproxeno (Aleve^®^)
- Corticoesteroides: Medicamentos que pueden aliviar el dolor y la hinchazón de la RA por un tiempo breve
- Medicamentos antirreumáticos modificadores de la enfermedad (DMARD): Medicamentos que pueden disminuir los síntomas, retardar o detener el daño a las articulaciones y mejorar la capacidad de realizar las actividades diarias

A veces, los DMARD y los corticoesteroides se toman juntos para tratar la RA. Este resumen analiza las investigaciones sobre la eficacia de los DMARD cuando se toman solos o con corticoesteroides.

## Conozca sus opciones

### ¿Qué son los DMARD?

Los DMARD son una familia de medicamentos que impiden que el sistema inmunológico ataque y destruya las articulaciones. Si usted tiene síntomas graves de RA o no obtiene alivio suficiente con los analgésicos o los corticoesteroides, tal vez su médico le sugiera tomar un DMARD. Los DMARD pueden tomarse juntos o con otros analgésicos y corticoesteroides.

Existen dos tipos de DMARD: los no biológicos y los biológicos.

#### DMARD no biológicos

Al igual que la mayoría de los medicamentos, los DMARD no biológicos se fabrican con sustancias químicas. Por lo general se toman una vez al día o una vez a la semana en forma de pastillas, pero algunos pueden también inyectarse. El grupo de DMARD no biológicos incluye:

- Hidroxicloroquina (Plaquenil^®^)
- Leflunomida (Arava^®^)
- Metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^)
- Sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^)

#### DMARD biológicos

Los DMARD biológicos son proteínas similares a las que el cuerpo produce, pero estas proteínas se fabrican en laboratorios. Los DMARD biológicos deben administrarse en forma de inyección o mediante un tubo intravenoso (IV) colocado en una vena del brazo. El grupo de DMARD biológicos incluye:

- Abatacept (Orencia^®^)
- Adalimumab (Humira^®^)
- Anakinra (Kineret^®^)
- Certolizumab pegol (Cimzia^®^)
- Etanercept (Enbrel^®^)
- Golimumab (Simponi^®^)
- Infliximab (Remicade^®^)
- Rituximab (Rituxan^®^)
- Tocilizumab (Actemra^®^)

Algunos DMARD biológicos, como infliximab (Remicade^®^), rituximab (Rituxan^®^) y tocilizumab (Actemra^®^), deben administrarse por medio de un tubo intravenoso (IV) en un consultorio médico o clínica. El procedimiento puede tardar hasta 2 horas. Otros DMARD biológicos vienen en forma de plumas inyectoras que puede usar en casa.

La mayoría de los DMARD biológicos se administran una vez al mes, cada dos semanas o cada semana. Su médico puede cambiar el plan, dependiendo de su mejoría.

### ¿Cuáles son los posibles efectos secundarios de los DMARD no biológicos y biológicos?

Debido a que los DMARD no biológicos y biológicos actúan de manera distinta, también tienen diferentes efectos secundarios, algunos de ellos graves.

Posibles efectos secundarios que causan los DMARD

DMARD no biológicos | DMARD biológicos
- Malestar estomacal; - Náusea; - Diarrea; - Pérdida de cabello; - Úlceras en la boca; - Salpullido o reacciones graves en la piel; - Problemas del hígado, los riñones o los pulmones | - Enrojecimiento, hinchazón, comezón, moretones o dolor en la zona donde se aplicó la inyección; - Sinusitis (dolor de garganta, secreción nasal, ronquera); - Dolor de cabeza; - Náuseas; - Diarrea
Posibles efectos secundarios graves
- En casos raros, el DMARD no biológico metotrexato y algunos DMARD biológicos (incluidos adalimumab [Humira^®^], etanercept [Enbrel^®^], golimumab [Simponi^®^] e infliximab [Remicade^®^]) se han vinculado con:; - Infecciones graves, como la tuberculosis (llamada “TB”); infecciones por hongos, como la candidiasis; neumonía o enfermedades adquiridas por alimentos, como listeriosis; - Cáncer, por lo común linfoma (cáncer de los ganglios linfáticos, que son parte del sistema inmunológico); - El riesgo de infecciones graves o cáncer es mayor cuando se toman dos o más DMARD biológicos juntos o se toma un DMARD biológico junto con un DMARD no biológico. Se desconoce cuál es exactamente el riesgo que corren las personas con RA que toman un DMARD.; - El rituximab (Rituxan^®^) puede causar una reacción grave la primera vez que se toma. También puede causar una erupción en la piel y poner en peligro su vida.

Esta información proviene de las etiquetas de estos medicamentos aprobadas por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos.

### ¿Que son los corticoesteroides?

Los corticoesteroides son medicamentos que tienen un efecto similar al de cierto tipo de hormonas corporales. Los corticoesteroides pueden ayudar a reducir la hinchazón e impedir que el sistema inmunológico ataque a las articulaciones sanas. Los corticoesteroides se administran en forma de pastillas, líquidos o inyecciones e incluyen:

- Metilprednisolona (Depo Medrol^®^, Medrol^®^, Solu-Medrol^®^)
- Prednisolona (Delta-Cortef^®^, Econopred^®^, Orapred^®^, Pediapred^®^, Prelone^®^)
- Prednisona (Liquidpred^®^, Deltasone^®^, Sterapred^®^)

### ¿Cuáles son los posibles efectos secundarios de los corticoesteroides?

Los efectos secundarios posibles de los corticoesteroides, según establece la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA por su sigla en inglés) de Estados Unidos, incluyen:

- Hinchazón de las pantorrillas
- Aumento de peso
- Aumento de la presión arterial
- Cambios de humor repentinos
- Aumento de la presión en los ojos

Los posibles efectos secundarios por tomar corticoesteroides durante más de unos días o semanas incluyen:

- Azúcar alta en la sangre, que puede causar o empeorar la diabetes
- Aumento del riesgo de infección
- Pérdida de calcio en los huesos, que puede aumentar el riesgo de fracturas
- Períodos menstruales irregulares
- Piel fina, propensa a moretones
- Cicatrización lenta de las heridas

### ¿Qué dicen las investigaciones acerca de los DMARD no biológicos?

Qué tan eficaces son para tratar la RA:

- El metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^) y la sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^) actúan de manera similar para aliviar los síntomas, reducir el número de articulaciones afectadas, mejorar la capacidad para las actividades diarias y retardar o detener el daño a las articulaciones.
- La leflunomida (Arava^®^) parece ser tan eficaz como el metotrexato, pero no se ha investigado lo suficiente para saberlo con certeza.

Efectos secundarios:

- Todos los DMARD no biológicos parecen causar una cantidad similar de efectos secundarios, pero no existe suficiente investigación para saberlo con certeza.

### ¿Qué dicen las investigaciones sobre los DMARD biológicos?

Qué tan eficaces son para tratar la RA:

- Los DMARDS biológicos disminuyen o detienen totalmente los síntomas, mejoran la capacidad para las actividades diarias y retardan o detienen el daño a las articulaciones.

Efectos secundarios:

- El uso de un DMARD biológico aumenta el riesgo de desarrollar infecciones graves.
- El tomar DMARD biológicos por mucho tiempo no aumenta el riesgo de padecer efectos secundarios graves.

### ¿Qué dicen las investigaciones sobre combinar medicamentos?

Qué tan eficaces son para tratar la RA:

- Si el tratamiento con un DMARD no alivia los síntomas, tomar un DMARD biológico junto con el DMARD no biológico metotrexato, funciona mejor que tomar sólo uno para mejorar la capacidad de realizar actividades diarias y retardar o detener el daño a las articulaciones.
- El añadir un corticoesteroide al tratamiento con un DMARD no biológico mejora más la capacidad de realizar actividades diarias que tomar solamente un DMARD no biológico. El añadir un corticoesteroide puede también retardar o detener más el daño a las articulaciones que tomar solamente un DMARD no biológico, pero no existe suficiente investigación para saberlo con certeza.
- En las personas que han tenido RA por menos de 3 años, tomar dos o tres DMARD no biológicos, más un corticoesteroide, funciona mejor que tomar solamente un DMARD no biológico.
- En las personas que han tenido RA por menos de 3 años, tomar el DMARD no biológico metotrexato junto con un DMARD biológico disminuye o detiene totalmente los síntomas y retrasa o detiene el daño a las articulaciones en las personas con una RA que estaba empeorando rápidamente.
- En las personas que han tenido RA durante mucho tiempo sin ninguna mejoría, tomar tres DMARD no biológicos juntos reduce más los síntomas y el número de articulaciones afectadas que tomar uno o dos DMARD no biológicos.

Efectos secundarios:

- Tomar un DMARD no biológico con un DMARD biológico no causa más efectos secundarios que tomar solamente el DMARD biológico.
- Tomar dos o más DMARD biológicos juntos puede causar más efectos secundarios graves que tomar solamente uno.
- Tomar un corticoesteroide junto con un DMARD no biológico no hace que el tratamiento sea más difícil de tolerar.
- En las personas que han tenido RA por menos de 3 años, tomar dos o tres DMARD no biológicos más un corticoesteroide no hace que el tratamiento sea más difícil de tolerar que tomar solamente un DMARD no biológico.

### ¿Qué dicen las investigaciones sobre la comparación entre los DMARD no biológicos y los biológicos?

Qué tan eficaces son para tratar la RA:

- Los DMARD biológicos adalimumab (Humira^®^) y etanercept (Enbrel^®^) ayudan a disminuir los síntomas casi igual que el DMARD no biológico metotrexato.

Efectos secundarios:

- No se ha investigado lo suficiente para saber si determinados efectos secundarios ocurren con mayor frecuencia con los DMARD no biológicos o los biológicos.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se necesitan más investigaciones para saber qué medicamentos para la RA funcionarían mejor en cada caso. Deben considerarse varias cosas cuando se elija un medicamento para tratar su RA:

- Hasta qué punto los beneficios compensan los efectos secundarios posibles de cada medicamento.
- Qué medicamento se adapta mejor a su estilo de vida, lo que usted considera importante (sus valores) y sus preferencias.
  - Tal vez quiera considerar si prefiere que el medicamento se administre en pastillas, inyecciones o por un tubo intravenoso. Tal vez quiera también considerar con qué frecuencia puede ir al consultorio o la clínica y cuánto tiempo tiene disponible para estar allí.
- El costo de cada medicamento.

### ¿Hasta qué punto los riesgos compensan los beneficios?

Solamente usted y su médico pueden decidir si el uso de cierto DMARD para tratar la RA compensa el riesgo de los posibles efectos secundarios. Usted y su médico deben hablar acerca de:

- El grado de dolor o daño que tenga en las articulaciones y si el tratamiento con un DMARD puede ayudar
- El riesgo de padecer efectos secundarios graves a causa de los DMARD
- Signos a los que debe estar atento para detectar efectos secundarios graves, a fin de que puedan tratarse o se pueda cambiar el medicamento
- Si convendría añadir un corticoesteroide a su tratamiento con DMARD
- Otras opciones, además de los DMARD, que puedan aliviar su RA

### ¿Cuáles son los costos?

Los costos para usted de los DMARD no biológicos, biológicos y los corticoesteroides dependen de:

- Su plan de seguro médico
- La cantidad (dosis) que necesite
- Si el medicamento se puede administrar en pastillas, en inyecciones o por un tubo intravenoso
- Si existe una forma genérica del medicamento
- Si el laboratorio que fabrica el medicamento ofrece asistencia económica para reducir el costo

Los corticoesteroides pueden tomarse por periodos breves (30 días) o por más tiempo, dependiendo de sus necesidades específicas. El costo de los corticoesteroides es de alrededor de $3 a $15 por mes. El costo para usted depende de cuánto medicamento necesite y cuánto tiempo deberá tomarlo.

Precios de mayoreo: DMARD no biológicos y biológicos

Nombre del medicamento | Nombre comercial | Precio por mes^*^ | Forma | Dosis
DMARD no biológicos
Hidroxicloroquina | Genérico | $35–$75 | Tableta | 200–400 mg al día
Hidroxicloroquina | Plaquenil^®^ | $110–$215 | Tableta | 200–400 mg al día
Leflunomida | Genérico | $490 | Tableta | 20 mg al día
Leflunomida | Arava^®^ | $910 | Tableta | 20 mg al día
Metotrexato | Genérico | $45–$90 | Tableta | 7.5–15 mg por semana
Metotrexato | Folex^®^, Rheumatrex^®^, Trexall^®^ | $125–$140 | Tableta | 7.5–15 mg por semana
Sulfasalazina | Genérico | $40 | Tableta | 2,000 mg al día
Sulfasalazina | Azulfidine EN-Tabs^®^ | $120 | Tableta | 2,000 mg al día
Sulfasalazina | Sulfazine^®^ | $30 | Tableta | 2,000 mg al día
DMARD biológicos (no existen versiones genéricas de estos medicamentos)
Abatacept | Orencia^®^ | $1,430–$2,860 | IV | 500–1,000 mg al mes
Abatacept | Orencia^®^ | $2,530 | Inyección | 125 mg por semana
Adalimumab | Humira^®^ | $2,450 | Inyección | 40 mg dos veces al mes
Anakinra | Kineret^®^ | $2,760 | Inyección | 100 mg al día
Certolizumb pegol | Cimzia^®^ | $2,360 | Inyección | 400 mg al mes
Etanercept | Enbrel^®^ | $2,475 | Inyección | 50 mg por semana
Golimumab | Simponi^®^ | $2,650 | Inyección | 50 mg al mes
Infliximab | Remicade^®^ | $3,725–$9,300 | IV | 200 a 500 mg dos veces al mes (según su peso)
Rituximab | Rituxan^®^ | $15,180 | IV | 1,000 mg dos veces al mes
Tocilizumab | Actemra^®^ | $1,660–$3,320 | IV | 400–800 mg al mes (según su peso)

* Los precios son los precios promedio de mayoreo según el RED BOOK Online^®^ redondeados a los $5 más cercanos. Los precios del medicamento genérico son el valor promedio de los precios publicados por los distintos fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los de la lista, dependiendo de su seguro médico y del fabricante al que compre su farmacia.

IV = vía intravenosa

### Pregunte a su médico

- ¿Cree usted que un DMARD puede ayudarme con la RA?
- ¿A qué efectos secundarios graves debo prestar atención?
- ¿Agregar un corticoesteroide a un DMARD puede ayudarme con la RA?
- ¿En cuánto tiempo empezaré a sentirme mejor?
- ¿Hay algún medicamento menos costoso que pueda tomar?
- ¿Qué más puedo hacer para ayudar a aliviar mi RA?
- ¿Hay cambios específicos con mi estilo de vida que me pueda sugerir y me puedan ayudar?

#### Otras preguntas para su médico

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

#### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Drug Therapy for Rheumatoid Arthritis in Adults: An Update (Tratamiento con medicamentos de la artritis reumatoide en adultos: actualización), publicado en abril de 2012.

El informe fue producido por RTI International–University of North Carolina Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Carolina del Norte–RTI International) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/dmardsra.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Este servicio está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con artritis reumatoide.

Esta guía fue traducida de la publicación en inglés titulada Medicines for Rheumatoid Arthritis: A Review of the Research for Adults.

* En este resumen, la palabra “médico” se refiere a todos los profesionales de la atención médica que puedan atenderlo, lo que incluye a su médico, reumatólogo, enfermera o asistente médico.