# Medicamentos para la artritis reumatoide

Guía para adultos

## Hechos resumidos

- Los medicamentos para la artritis reumatoide (AR) pueden disminuir el avance de la enfermedad y reducir el daño en las articulaciones. También pueden aliviar el dolor y hacen más fácil el llevar a cabo tareas diarias.
- La mayoría de las personas pueden encontrar un medicamento AR que funciona.
- Si un medicamento AR no está funcionando lo suficientemente bien, usted tiene otras opciones. El cambiarse a un medicamento AR diferente o añadir otro tipo de medicamento AR puede ser de ayuda.
- Los esteroides también se utilizan frecuentemente con otros medicamentos AR. Ellos ayudan con el dolor en las articulaciones y la hinchazón. Sin embargo, el utilizarlo por largo tiempo puede causar efectos secundarios.
- Los medicamentos AR pueden aumentar las posibilidades de infecciones u otros efectos secundarios. Las revisiones médicas regulares y pruebas de sangre son formas para detectar estos problemas temprano.

## ¿Qué cubre esta guía?

Esta guía puede ayudarle a trabajar con su médico o enfermera para encontrar un medicamento para la artritis reumatoide (AR). La artritis reumatoide es una condición para toda la vida. La AR causa inflamación (hinchazón, enrojecimiento, y dolor) que puede deteriorarle las articulaciones. No existe tratamiento para curar la AR. Pero los medicamentos en esta guía pueden disminuir el avance de la enfermedad y ayudarle a que se sienta mejor.

Esta guía está basada en una revisión de investigación auspiciada por el gobierno sobre medicamentos AR.

Además de ayudarle a conocer sobre lo que sucede con la AR, esta guía le explica los beneficios, riesgos y los costos de los medicamentos AR.

## ¿Qué no está cubierto en esta guía?

Esta guía no cubre todas las maneras de manejar la AR. No cubre los analgésicos, como el acetaminofén (Tylenol^®^), ibuprofeno (Advil^®^, Motrin^®^), y morfina. No cubre los medicamentos AR más antiguos y que ya no se utilizan mucho. Esta guía no trata con otras formas para ayudarle a sentirse mejor, como una buena mezcla de ejercicio, descanso, y el comer saludable.

## Aprenda sobre la artritis reumatoide (AR)

### ¿Qué causa la AR?

Nadie sabe con certeza que causa la AR. Es un problema autoinmune. Esto significa que el sistema de defensa de su cuerpo (conocido como sistema inmunológico) ataca sus propias articulaciones y órganos. Esto puede causar hinchazón del sinovial, el tejido que reviste las articulaciones.

### ¿Qué ocurre sin tratamiento?

Sin tratamiento, la AR puede destruirle lentamente las articulaciones. La hinchazón del sinovial daña el cartílago, los huesos y tendones. Las articulaciones se vuelven más y más dolorosas, rígidas y se hinchan. Esto puede que dificulte realizar las tareas diarias. La AR también puede afectar los ojos, los vasos sanguíneos, y el revestimiento del corazón. También puede causar un recuento bajo de los glóbulos rojos, debilidad en los huesos, y cicatrización en los pulmones.

## Conozca sobre los medicamentos para la AR

Los medicamentos son el tratamiento principal para la AR. Ellos reducen la hinchazón en las articulaciones y alivian el dolor. La mayoría de las personas necesitan tomar los medicamentos AR de por vida. Esta guía habla sobre dos formas de medicamentos AR, los DMARDs (se pronuncia Di-mards, por sus siglas en inglés) y los esteroides.

### DMARDs

Los medicamentos que funcionan mejor para la AR son conocidos como DMARDs. DMARDs significa Disease-Modifying AntiRheumatic Drug (Medicamento antirreumático modificador de la enfermedad). Estos medicamentos no sólo alivian el dolor. También demoran o detienen los cambios en sus articulaciones.

Los DMARDs vienen en dos grupos. Algunos son pastillas. Los otros se administran por medio de inyecciones o IV. Ambos suprimen el sistema inmunológico. Esto significa que hacen más lento el ataque del cuerpo a sí mismo.

### Esteroides

Los esteroides ayudan con el dolor en las articulaciones y la hinchazón, pero no se sabe si pueden disminuir el avance de la enfermedad. La prednisona es el nombre de un esteroide que se utiliza con frecuencia para la AR.

DMARDs

Nombre genérico | Nombre de la marca
Pastillas
Hidroxicloroquina | Plaquenil^®^
Leflunomida | Arava^®^
Metotrexato | Rheumatrex^®^ Trexall^®^
Sulfasalazina | Azulfidine^®^ Sulfazine^®^
Inyecciones (debajo de la piel)
Adalimumab | Humira^®^
Anakinra | Kineret^®^
Etanercept | Enbrel^®^
Por medio de IV
Abatacept | Orencia^®^
Infliximab | Remicade^®^
Rituximab | Rituxan^®^

## Aprenda sobre los beneficios

Las investigaciones muestran que los DMARDs funcionan. Ellos pueden disminuir el avance de la enfermedad y aliviar el dolor. Pero es difícil predecir cuál medicamento funcionará mejor para cada persona. Cerca de 65 de cada 100 personas necesitan cambiar su medicamento AR. Algunas personas cambian porque su medicamento no les está funcionando lo suficientemente bien. Otros se cambian por los efectos secundarios.

Algunos de los medicamentos se han comparado unos con otros en estudios de investigación. Esto es lo que sabemos de acuerdo a esta investigación.

### Comience con su primer medicamento AR

- Metotrexato (Rheumatrex^®^, Trexall^®^), es una pastilla DMARD que se utiliza con frecuencia. Funciona tan bien como el DMARD que se suministra por inyección o IV.
- Dos otras pastillas DMARD, leflunomida (Arava^®^) y la sulfasalazina (Azulfidine^®^, Sulfazine^®^), funcionan tan bien como el metotrexato (Rheumatrex^®^, Trexall^®^).
- Adalimumab (Humira^®^), etanercept (Enbrel^®^), e infliximab (Remicade^®^) funcionan todas de forma similar.

### Cambie y combine medicamentos AR

- Si el metotrexato (Rheumatrex^®^, Trexall^®^) no está funcionando lo suficientemente bien, usted tiene opciones. El añadir un DMARD que se inyecta o se administra por IV trabaja mejor que el metotrexato por sí solo.
- El combinar la prednisona con hidroxicloroquina (Plaquenil^®^), metotrexato (Rheumatrex^®^, Trexall^®^), o sulfasalazina (Azulfidine^®^, Sulfazine^®^), funciona mejor que cualquiera de estas pastillas DMARD por sí solas.

### Algunos no funcionan muy bien

- La anakinra (Kineret^®^) es un DMARD por inyección que no funciona tan bien como las otras inyecciones.
- El combinar metotrexato (Rheumatrex^®^, Trexall^®^) y sulfasalazina (Azulfidine^®^, Sulfazine^®^) no funciona mejor que cualquiera de las pastillas DMARD por sí solas.

## Aprenda sobre los riesgos

### Infecciones

- Los medicamentos AR debilitan las defensas del cuerpo. Esto significa que infecciones serias, como la neumonía tienen una mayor probabilidad de ocurrir con estos medicamentos. Una infección seria necesita antibióticos y casi siempre debe ser tratada en un hospital.

### Otros problemas serios

- El metotrexato (Rheumatrex^®^, Trexall^®^) puede causar problemas del hígado y de los riñones. También puede causar un recuento bajo de glóbulos rojos y úlceras bucales dolorosas.
- Los esteroides como la prednisona pueden debilitar los huesos, subir el azúcar en la sangre, y causar aumento de peso. Por esta razón, los esteroides se prescriben usualmente en dosis bajas y por corto tiempo.

### Reacciones a las inyecciones

- Las inyecciones de DMARD pueden causar enrojecimiento, picazón, salpullido y dolor en el punto donde se suministra la inyección. Más personas que toman anakinra (Kineret^®^) tienen estas reacciones que las personas que usan otras inyecciones DMARD.
- Cerca de la mitad de las personas que reciben DMARDs por IV tienen una reacción. Sienten escalofríos, mareo o se enferman del estómago. Pero sólo cerca de 2 de cada 100 personas suspenden su medicamento debido a las reacciones.
- Es raro, pero los DMARDs que se suministran por IV también pueden causar una reacción seria, como una convulsión.

### Riesgos de defectos de nacimiento serios

- El metotrexato (Rheumatrex^®^, Trexall^®^), y la leflunomida (Arava^®^) pueden causar defectos de nacimiento serios.
- Tanto los hombres como las mujeres que toman estas pastillas DMARD deben hablar con su médico o enfermera antes de planear un embarazo.
- Asegúrese de usar dos métodos de control de natalidad mientras toma estas pastillas DMARD. Por ejemplo, puede usar pastillas contra el embarazo y un condón cada vez que tiene relaciones sexuales.

## Hable con su médico o enfermera sobre los medicamentos AR

### Beneficios

Los DMARDs reducen la hinchazón y le facilitan hacer las tareas diarias. También ayudan a prevenir daño en las articulaciones y discapacidad a largo plazo. La mayoría de las personas pueden encontrar un DMARD que les funciona. Hágale estas preguntas a su médico o enfermera.

### ¿Necesito una inyección o puedo tomar una pastilla?

- La mayoría de las personas pueden comenzar con la pastilla DMARD. Muchas personas obtienen buenos resultados cuando comienzan con metotrexato (Rheumatrex^®^, Trexall^®^). Puede funcionar tan bien como el DMARD que se administra por inyección o IV.

### ¿Cuánto tiempo pasará antes de que me sienta mejor?

- Los DMARDs no comienzan a funcionar de inmediato. Pueden tomar semanas o meses antes de que empiecen a trabajar.
- Su médico o enfermera pueden prescribirle un analgésico hasta que el DMARD comience a funcionar.

### ¿Qué ocurre si el primer medicamento no funciona o deja de funcionar?

- Cambiarse a otro DMARD puede ayudarle.
- Añadir un segundo tipo de DMARD puede que le funcione. Si está tomando metotrexato (Rheumatrex^®^, Trexall^®^), el añadir un DMARD por inyección o IV puede ayudarle.
- Añadir prednisona a una pastilla DMARD también es una opción.

## Reduzca sus riesgos

### Visite a su médico o enfermera para revisiones médicas regulares y pruebas de sangre

- Las revisiones y las pruebas de sangre ayudarán a detectar infecciones u otros problemas temprano.

### Manténgase alejado de personas que están enfermas

- Llame a su médico o enfermera de inmediato si tiene síntomas de infección, como fiebre o tos.

### Asegúrese que su inyección de la influenza (flu, en inglés) y de neumonía estén al día

- Estas inyecciones pueden ayudarle a combatir infecciones. Verifique con su médico o enfermera antes de ponerse cualquiera otra vacuna.

### Asegúrese de injerir suficiente calcio y vitamina D

- La AR debilita los huesos. Usted puede ayudar a mantener sus huesos saludables consumiendo suficiente calcio y vitamina D. La leche, el yogur y los vegetales de hojas verdes son altos en calcio. También puede tomar pastillas de calcio y vitamina D.

## Dosis y precio de los DMARDs y esteroides

Utilice la tabla abajo para comparar los precios de los medicamentos. Algunos DMARDs vienen en forma genérica, los cuales cuestan menos. Si su plan de seguro médico cubre prescripciones, verifique con ellos sobre el costo. Si necesita ayuda para pagar los medicamentos AR, puede que exista un programa para usted. El Partnership for Prescription Assistance (Sociedad para la Asistencia con Prescripciones) puede informarle sobre estos programas. Sitio de Internet en español: www.pparx.org/es. Teléfono: 1-888-477-2669.

Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Precio para provisión de 1 mes^3^
Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Genérico | Marca
Pastillas DMARD
Hidroxicloroquina | Plaquenil^®^ | 400 mg una vez al día | $70 | $125
Leflunomida | Arava^®^ | 10 mg una vez al día | $495 | $570
Leflunomida | Arava^®^ | 20 mg una vez al día | $495 | $570
Metotrexato | Rheumatrex^®^, Trexall^®^ | 7.5 mg una vez por semana | $40 | $45
Metotrexato | Rheumatrex^®^, Trexall^®^ | 15 mg una vez por semana | $80 | $90
Metotrexato | Rheumatrex^®^, Trexall^®^ | 20 mg una vez por semana | $105 | $120
Sulfasalazina | Azulfidine^®^, Sulfazine^®^ | 500 mg dos veces al día | $15 | $30
Sulfasalazina | Azulfidine^®^, Sulfazine^®^ | 1,000 mg dos veces al día | $30 | $60
Sulfasalazina | Azulfidine^®^, Sulfazine^®^ | 1,500 mg dos veces al día | $45 | $85
Sulfasalazina
Sulfasalazina | Azulfidine EN-tabs^®^ | 1,000 mg una vez al día | $25 | $35
Sulfasalazina | Azulfidine EN-tabs^®^ | 2,000 mg una vez al día | $45 | $70
Sulfasalazina | Azulfidine EN-tabs^®^ | 3,000 mg una vez al día | $70 | $100
Inyecciones DMARD (debajo de la piel)
Adalimumab | Humira^®^ | 40 mg cada 2 semanas | ND | $1,585
Anakinra | Kineret^®^ | 100 mg una vez al día | ND | $1,445
Etanercept | Enbrel^®^ | 25 mg dos veces a la semana | ND | $1,585
Etanercept | Enbrel^®^ | 50 mg una vez a la semana | ND | $1,585
DMARDs por medio de IV
Abatacept | Orencia^®^ | 500 mg cada 4 semanas | ND | $1,080
Abatacept | Orencia^®^ | 750 mg cada 4 semanas | ND | $1,620
Abatacept | Orencia^®^ | 1,000 mg cada 4 semanas | ND | $2,160
Infliximab | Remicade^®^ | 210 mg cada 8 semanas^4^ | ND | $730
Infliximab | Remicade^®^ | 420 mg cada 8 semanas^4^ | ND | $1,465
Infliximab | Remicade^®^ | 700 mg cada 8 semanas^4^ | ND | $2,440
Rituximab | Rituxan^®^ | 1,000 mg total de 2 dosis | ND | $1,015^5^
Esteroides
Prednisolona (líquido) | Varios nombres de marcas | 5 mg una vez al día | $15 | $25
Prednisolona (líquido) | Varios nombres de marcas | 7.5 mg una vez al día | $25 | $40
Prednisolona (líquido) | Varios nombres de marcas | 10 mg una vez al día | $30 | $55
Prednisona (pastillas) | Varios nombres de marcas | 5 mg una vez al día | $2 | $3
Prednisona (pastillas) | Varios nombres de marcas | 7.5 mg una vez al día | $3 | $5
Prednisona (pastillas) | Varios nombres de marcas | 10 mg una vez al día | $3 | $6

1 Estos medicamentos fueron incluidos en los estudios de investigación.

2 Las dosis son similares a las que se usaron en los estudios de investigación o típicas para artritis reumatoide.

3 El precio al por mayor promedio del Drug Topics Red Book, 2007. El precio listado no incluye gastos por IV.

4 La dosis varía de acuerdo al peso del cuerpo. La dosis fue calculada en base a una persona de 154 libras.

5 El precio ($12,180) es por un promedio de 12 meses.

DMARDs=medicamentos antirreumáticos modificadores de la enfermedad, EN=acción prolongada, IV=intravenosa, ND=no está disponible como genérico.

## ¿Qué no se conoce aún?

- Las investigaciones no pueden decirnos aún como las pastillas DMARD, además del metotrexato (Rheumatrex^®^, Trexall^®^), se comparan con los DMARDs que se suministran por inyección o IV.
- Las investigaciones aún no nos pueden decir como el abatecept (Orencia^®^) y rituximab (Rituxan^®^) se compara con otros DMARDs.

## ¿Dónde puedo obtener más información?

Para una copia electrónica de esta guía y los materiales sobre la comparación de tratamientos y medicamentos para otras condiciones, visite nuestro sitio en la red: http://effectivehealthcare.ahrq.gov/spanishInfo.cfm

Para recibir una copia impresa gratis llamar al: AHRQ Publications Clearinghouse (800) 358-9295 (para español oprima el #2) Pida la publicación de AHRQ número 08(09)-EHC004-B

Para más información en español sobre la artritis reumatoide, visite el sitio de Medline Plus: http://www.nlm.nih.gov/medlineplus/spanish/rheumatoidarthritis.html

## ¿Cuál es la fuente de esta guía?

La información en esta guía proviene de una revisión detallada de 156 reportes de investigación. La revisión se titula Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults (Efectividad Comparativa de la Terapia con Medicamentos para la Artritis Reumatoide y la Artritis Psoriásica en los Adultos) (2007) y fue escrito por el RTI-University of North Carolina Evidence-based Practice Center.

## Related Content

Research Review

Clinician Guide

Consumer Guide