# Tratamiento para el cáncer de próstata

Guía para hombres con cáncer localizado de próstata

La mayoría de los hombres con cáncer de próstata tienen tiempo para evaluar las diversas opciones de tratamiento.

Usted tiene tiempo para hablar con su familia y estudiar sus opciones con su médico o enfermera. Esta guía puede ayudarle a decidir cuál de ellas le conviene más, ahora y en el futuro.

## Hechos resumidos

- Se calcula que en 9 de cada 10 casos de cáncer de próstata la enfermedad no se ha diseminado más allá de la próstata. Es lo que se llama cáncer localizado de próstata.
- La mayoría de los hombres con cáncer localizado de próstata sobreviven al cáncer. Esto se logra con observación vigilante o cualquier tratamiento activo.
- La investigación todavía no ha demostrado cuál es la mejor opción para tratar el cáncer localizado de próstata. Cada hombre tendrá que decidir de acuerdo con lo que piense sobre de los riesgos y beneficios.
- Los hombres que se someten a cirugía de próstata tienen mayor probabilidad de sobrevivir al cáncer que los que se tratan con observación vigilante.
- Los tratamientos del cáncer de próstata pueden causar problemas a largo plazo en la actividad sexual, las vías urinarias, y el intestino.
- Los hospitales y cirujanos que hacen más operaciones de próstata, tienen mejores resultados.

## ¿Qué cubre esta guía?

Esta guía puede ayudarle a colaborar con su médico para tratar el cáncer localizado de próstata. La información proviene de una revisión financiada por el gobierno acerca de la investigación de los tratamientos del cáncer localizado de próstata. Abarca la investigación referente a cuatro tratamientos comunes del cáncer de próstata y sus efectos secundarios.

Observación vigilante—vigilancia cuidadosa del cáncer a través del tiempo, mediante chequeos regulares.

Cirugía de próstata—llamada también prostatectomía radical.

Radiación—puede ser de tipo haz externo o de tipo braquiterapia (o “siembra”).

Tratamiento hormonal.

## ¿Qué no cubre esta guía?

Esta guía no cubre cómo se puede prevenir el cáncer de próstata. Tampoco habla de otros métodos de tratamiento, como el ultrasonido, la crioterapia (congelación), la cirugía laparoscópica (llamada también “de curita” o de ojo de cerradura), ni la cirugía robótica. Son tratamientos nuevos cuya eficacia no se ha investigado aún lo suficiente, a diferencia de los otros. Esta guía tampoco habla de los productos herbarios (como el té verde) ni de las vitaminas y minerales (como el selenio). No incluye tratamientos para el cáncer de próstata que ya se diseminó fuera de la próstata, como la quimioterapia.

## ¿Cómo se descubre el cáncer de próstata?

En la mayoría de los hombres con cáncer localizado de próstata los síntomas son muy pocos o nulos. Estos tipos de cánceres suelen descubrirse durante un examen rutinario o por medio de pruebas de detección. Las pruebas más comunes son el examen rectal digital y un análisis de sangre llamado antígeno prostático específico (PSA, por sus siglas en inglés).

### Examen rectal digital

El médico o enfermera palpa la próstata con un dedo a través de la pared del recto. La finalidad es revisar la forma de la próstata y buscar bultos o zonas duras.

### Análisis del PSA en sangre

El PSA es una proteína elaborada por la próstata. Un análisis de sangre indica la cantidad de PSA presente en la sangre. En muchos casos de cáncer de próstata la cantidad de PSA es mayor de lo normal o ha aumentado con el tiempo.

Cuando el examen rectal digital o la prueba de PSA en la sangre dan un resultado anormal, pueden requerirse otros estudios. Entre ellos puede estar una biopsia de la próstata.

### Biopsia

En la biopsia, el médico extrae con una aguja fragmentos minúsculos de próstata. Estos fragmentos se examinan con un microscopio en busca de células cancerosas. Si la biopsia indica cáncer de próstata, el laboratorio le asignará una puntuación llamada Gleason.

Las puntuaciones de Gleason van del 2 al 10. Dan una idea de la rapidez con que avanza el cáncer. Una puntuación de Gleason baja (de 2 a 5) significa que el cáncer avanza lentamente. Una puntuación alta (de 8 a 10) significa que el cáncer es más “agresivo” y tiende a diseminarse más. La mayoría de los hombres con cáncer de próstata tienen una puntuación intermedia (6 a 7).

Las puntuaciones de Gleason bajas indican mayor probabilidad de sobrevivir al cáncer de próstata. Esto es así independientemente de la forma que se use para tratarlo, incluida la observación vigilante.

¿Qué es la próstata?

La próstata es una glándula que tiene el tamaño aproximado de una nuez. La tienen solamente los hombres. Elabora y almacena el líquido que transporta los espermatozoides. La próstata se encuentra situada junto a la vejiga y el recto (parte final del intestino grueso, antes del ano). Está justo debajo de la vejiga y rodea la uretra (el tubo por donde sale la orina de la vejiga).

Las gráficas muestran que las puntuaciones de Gleason más bajas tienen una mayor probabilidad de sobrevivir al cáncer próstatá. “Edad” se refiere a la edad en que se descubrió el cáncer. Los hombres incluidos en este estudio de investigación se sometieron a observación vigilante o al tratamiento hormonal. Téngase en cuenta que algunos hombres que sobrevivieron al cáncer de próstata murieron de otras causas.

## ¿Con qué opciones cuenta?

En el caso del cáncer localizado de próstata se tienen, entre otras, las siguientes opciones: observación vigilante, cirugía de próstata, radiación, y tratamiento hormonal. La elección puede ser difícil, porque deben considerarse muchos factores. La investigación no indica qué opción es la mejor. Todos los tratamientos activos pueden tener efectos secundarios duraderos. En muchos casos, el cáncer de próstata avanza lentamente durante el curso de la vida. Eso significa que los hombres tienen tiempo para informarse acerca de la enfermedad, las opciones de tratamiento, y los efectos secundarios.

Es posible que usted y su médico decidan aplicar un tratamiento activo en vez de la observación vigilante. En tal caso, querrá evaluar cuál le conviene más. El principal beneficio de un tratamiento activo es la mayor probabilidad de que el cáncer se pueda extirpar o destruir. La desventaja es que todos los tratamientos activos pueden tener efectos secundarios. Algunos de estos efectos pueden continuar por largo tiempo.

La investigación lleva tiempo

Esta guía se concentra en los resultados a largo plazo de los tratamientos. Todavía no existen investigaciones que comparen los efectos de los cuatro tratamientos con el paso del tiempo. Pero hay investigaciones que comparan entre sí algunos de los tratamientos. Algunos se han comparado después de 10 años y otros después de 5 años.

La mayoría de las investigaciones realizadas hasta ahora se iniciaron antes de que se generalizara la prueba del PSA. Hoy en día se utiliza la prueba ampliamente. La prueba ayuda a descubrir el cáncer antes, cuando es más pequeño. La investigación actual incluye a hombres cuyo cáncer de próstata se encontró mediante la prueba del PSA. No ha pasado el tiempo suficiente para conocer los resultados a largo plazo de esas investigaciones.

### Evaluación de sus opciones

Lo primero que se debe decidir es si conviene esperar y observar el cáncer o si se debe tratar de manera inmediata. Las opciones pueden ser diferentes de acuerdo con su salud general y los resultados de laboratorio.

#### ¿Cuál fue su puntuación de Gleason en el momento en que se descubrió el cáncer?

Una puntuación de Gleason baja por lo general significa que el cáncer avanza despacio.

Los tumores con puntuaciones de Gleason más altas (8 a 10) se llaman agresivos. Tienden mucho a crecer y diseminarse fuera de la próstata en un plazo de 5 años. Los hombres con puntuación de Gleason más alta pueden pensar que necesitan un tratamiento activo. Sin embargo, la investigación no ha demostrado si es mejor la observación vigilante o un tratamiento activo en hombres con puntuaciones de Gleason altas.

#### ¿Cómo influyen su edad u otros problemas de salud en sus opciones de tratamiento?

La edad y algunos problemas de salud pueden hacer más riesgosa la cirugía. Si tiene usted problemas serios del corazón o los pulmones, es posible que su médico le informe sobre otras opciones. Si le han administrado radiación anteriormente, no podrá usarse nuevamente esta terapia para tratar el cáncer de próstata. Consulte a su médico para saber cuáles son sus opciones.

### Observación vigilante

La observación vigilante (llamada también vigilancia activa o control expectante) significa observar cómo se comporta el cáncer con el transcurso del tiempo.

La observación vigilante no es lo mismo que no hacer nada. Significa que el cáncer se somete a una vigilancia minuciosa, mediante chequeos regulares. Cuando usted acude a su médico o enfermera, es posible que le hagan un examen rectal digital, una prueba del PSA en la sangre, una ultrasonografía o una biopsia, para revisar si el cáncer ha crecido.

#### ¿Cómo afecta la observación vigilante su bienestar?

Con la observación vigilante, el cáncer no se extrae ni se destruye. Usted y su médico estarán atentos a cualquier cambio que ocurra con el transcurso del tiempo. El cáncer puede no diseminarse. Pero si se extiende, su médico le indicará las opciones de tratamiento activo con que cuenta.

#### ¿Qué debo saber sobre los efectos secundarios?

El principal beneficio de la observación vigilante es la posibilidad de evitar los efectos secundarios del tratamiento activo, como la disfunción eréctil (ED, por sus siglas en inglés) y problemas urinarios. Tenga presente que también los hombres sometidos a observación vigilante pueden padecer estos problemas. Pueden ser causados por otros problemas de salud o por ciertos medicamentos.

### Cirugía de próstata

La cirugía de próstata (llamada también prostatectomía radical) es una operación en la que se extrae la próstata y el cáncer que ésta contiene. La uretra (tubo que conduce la orina) está rodeada por la próstata, así que también deberá extraerse una parte de ella. La porción de uretra restante se vuelve a conectar a la vejiga. Es posible que también se extraigan e inspeccionen en busca de cáncer otros tejidos cercanos a la próstata, como los ganglios linfáticos.

Los nervios que el varón necesita para tener erecciones están junto a la próstata. Estos pueden dañarse durante la operación, lo cual origina problemas para sostener una erección. Si el cáncer no se ha diseminado cerca de estos nervios, tal vez no sea necesario extraerlos.

Se ha realizado más investigación sobre la cirugía de próstata que sobre otros tratamientos activos.

#### ¿Qué diferencias existen entre la cirugía de próstata y la observación vigilante?

En general, la cirugía de próstata se realiza en hombres en buen estado físico y más jóvenes que los que se someten a observación vigilante o a otros tratamientos activos. Los riesgos de la cirugía de próstata aumentan conforme aumenta la edad. Al máximo, 10 de cada 100 hombres de 65 años y más padecen de problemas de corazón y pulmones después de la cirugía.

Los hombres que se tratan con cirugía de próstata tienen mayor probabilidad de sobrevivir al cáncer de próstata que los que se someten a observación vigilante. Un estudio de investigación en que se comparaba la cirugía de próstata con la observación vigilante indicó que:

- 90 de cada 100 hombres que se sometieron a cirugía de próstata sobrevivieron al cáncer por lo menos de 10 años.
- 85 de cada 100 hombres que utilizaron la observación vigilante sobrevivieron al cáncer por lo menos de 10 años.

Este estudio de investigación se inició antes de que se generalizara la prueba del PSA.

#### ¿Qué se logra al combinar el tratamiento hormonal con la cirugía de próstata?

La investigación indica que el uso de tratamiento hormonal antes de la cirugía de próstata no ofrece mejores resultados que si la operación se realiza sin tratamiento hormonal previo. El tratamiento hormonal administrado antes de la cirugía no ayuda los hombres a vivir más, ni evita que el cáncer se repita.

#### Más experiencia significa mejores resultados

La cirugía de próstata deja menos problemas cuando es realizada por cirujanos y en hospitales con mayor experiencia en esta operación.

- Los hombres tratados por cirujanos que realizan más de 10 operaciones de próstata cada año tienen menor probabilidad de presentar efectos secundarios duraderos. Tienen menos problemas, como goteo o escape de orina, que los hombres tratados por cirujanos que hacen menos operaciones.
- La cirugía deja menos problemas en los hombres tratados en hospitales donde se hacen más de 43 operaciones de próstata al año. Es menor la probabilidad de que presenten problemas de sangrado o problemas del corazón y de los pulmones.

### Radiación

La radiación mata las células cancerosas. El objetivo es dirigirla hacia el cáncer, evitando dañar las partes normales del cuerpo. La radiación puede aplicarse en dos formas: radiación de haz externo o braquiterapia. En algunos casos se emplean los dos tipos de radiación juntos.

La radiación de haz externo se concentra en la próstata por medio de un aparato. Este tipo de radiación se aplica en un hospital o clínica. La radiación se administra algunos minutos cada día durante 6 a 8 semanas.

En la braquiterapia (llamada también “siembra” de radiación) se aplican pequeñas semillas radiactivas en el tejido canceroso de la próstata con una aguja. Por lo general, este método requiere que el paciente acuda al hospital o clínica. Las semillas radiactivas introducidas en la próstata emiten con tiempo la radiación lentamente.

#### ¿Qué se sabe sobre la radiación?

- La probabilidad de que el cáncer de próstata se repita es menor en los hombres que reciben cantidades mayores de radiación.
- Los hombres que reciben cantidades mayores de radiación de haz externo tienen más probabilidades de tener diarrea y dolor rectal.
- La investigación no ha demostrado si los hombres que reciben cantidades mayores de radiación viven más tiempo.
- La investigación no ha demostrado si la radiación de haz externo o la siembra de radiación funciona mejor en el cáncer localizado de próstata.

#### ¿Qué ventajas ofrece la radiación sobre otras opciones?

La investigación no ha demostrado si los hombres que se tratan con radiación viven tanto como los que se someten a observación vigilante o a cirugía de próstata.

### Tratamiento hormonal

La testosterona es una hormona elaborada por el cuerpo. Ésta causa la multiplicación de las células del cáncer de próstata. El tratamiento hormonal disminuye o bloquea la testosterona del cuerpo. De esa manera ayuda a retardar o detener la multiplicación de las células cancerosas.

#### ¿Qué se sabe de los tratamientos hormonales?

Los tratamientos hormonales se administran en forma de inyecciones o pastillas. La mayor parte de la investigación sobre tratamientos hormonales se ha hecho con estos medicamentos: leuprolida (Lupron®, Viadur®, Eligard®), goserelina (Zoladex®), flutamida (Eulexin®) y bicalutamida (Casodex®). Los medicamentos hormonales suelen combinarse con cirugía de próstata o radiación. El tratamiento hormonal también puede usarse por sí solo.

La mayor parte de la investigación se refiere a la combinación de medicamentos hormonales con otras formas de tratamiento del cáncer de próstata. Se ha investigado menos el uso de los medicamentos hormonales por sí solos.

La bicalutamida (Casodex®), que se presenta en pastillas, no es útil para tratar el cáncer localizado de próstata. Ocurre así, independientemente de que se use sola o combinada con cirugía de próstata o con radiación de haz externo.

La investigación aún no ha demostrado si otros tratamientos hormonales pueden impedir por sí solos la diseminación del cáncer localizado de próstata.

#### ¿Qué pasa si el tratamiento hormonal se combina con radiación?

Los hombres que combinan los tratamientos hormonales con radiación de haz externo tienen mejores posibilidades de sobrevivir su cáncer de la próstata que los hombres que sólo se tratan con radiación. En un estudio de investigación en el que se comparó la radiación con y sin tratamiento hormonal se encontró que:

- 100 de un total de 100 hombres en quienes se combinó el tratamiento hormonal con la radiación de haz externo sobrevivieron al cáncer de próstata por un mínimo de 5 años.
- 94 de un total de 100 hombres que recibieron solamente radiación de haz externo sobrevivieron al cáncer de próstata por un mínimo de 5 años.

Este estudio de investigación no ha demostrado si la combinación del tratamiento hormonal con la radiación de haz externo cura el cáncer. Se requieren estudios de investigación más prolongados para observar todos los efectos de los tratamientos.

## ¿Qué efectos secundarios tiene el tratamiento?

Todos los tratamientos del cáncer de próstata pueden tener efectos secundarios. Los efectos secundarios más frecuentes son problemas sexuales, de las vías urinarias, y del intestino. Algunos de estos problemas se presentan poco después del tratamiento y otros con el transcurso del tiempo. Consulte a su médico o enfermera si tiene alguno de estos efectos secundarios. Puede haber formas de resolverlos.

La disfunción eréctil (ED) significa no poder sostener una erección para tener relaciones sexuales. La ED es el efecto secundario prolongado más frecuente. Puede suceder con cualquier tratamiento.

Los problemas urinarios son otro efecto secundario prolongado. Pueden consistir en escape o goteo de orina. A veces también significa no poder aguantar la orina en lo absoluto. Los problemas urinarios son más frecuentes después de la cirugía que con otros tratamientos.

Los problemas intestinales puedan presentarse como otro efecto secundario prolongado. A veces consisten en una “urgencia intestinal” (la necesidad apremiante de tener una evacuación sin poder esperar). Los problemas intestinales prolongados son más frecuentes después de la radiación de haz externo o del tratamiento hormonal que después de la cirugía de próstata o la observación vigilante.

Los tratamientos hormonales pueden tener otros efectos secundarios. Pueden causar calores (o sofocos), hinchazón de los pechos, y pérdida del impulso sexual. Pueden también causar cansancio, depresión, y problemas de la memoria. Los tratamientos hormonales pueden debilitar los huesos y aumentar la posibilidad de que se quiebren.

- 57 de cada 100 hombres que toman medicamentos hormonales tienen calores o sofocos (la sensación repentina de calor y sudor).
- 25 de cada 100 hombres que toman medicamentos hormonales tienen hinchazón de los pechos.

El siguiente cuadro muestra los resultados de la investigación sobre los efectos secundarios prolongados a los 2 años del tratamiento. Los problemas de erección son frecuentes con todos los tratamientos. Los problemas intestinales son más frecuentes con la radiación de haz externo. Los problemas urinarios son más comunes con la cirugía de próstata.

Comparación de efectos secundarios a los 2 años del tratamiento (número de hombres de cada 100)

| Observación vigilante | Cirugía de próstata | Radiación de haz externo | Tratamiento hormonal
Disfunción eréctil (ninguna erección en absoluto) | 33 | 58 | 43 | 86
Problemas urinarios (escape de orina) | 7 | 35 | 12 | 11
Problemas intestinales (urgencia intestinal) | 16 | 14 | 29 | 16

### Preguntas para su médico

¿Qué tan agresivo es mi cáncer? ¿Qué puntuación de Gleason tiene mi tumor de próstata? ¿Cuáles son los resultados de mi PSA y otros exámenes?

¿Cuánto tiempo tengo para escoger un tratamiento?

Dados mis otros problemas de salud, ¿me conviene más una opción determinada?

¿Con quién más debo hablar sobre la observación vigilante? ¿La cirugía de próstata? ¿La radiación? ¿El tratamiento hormonal?

¿Cuáles son mis riesgos con esta opción?

¿Qué probabilidad existe de que mi cáncer se repita después del tratamiento?

¿Qué opción me causará menos problemas de erección? ¿De escape de orina?

¿Qué posibilidad hay de que pueda tener relaciones sexuales después del tratamiento?

¿Cuántos de estos tratamientos realiza usted cada año?

¿Existe ayuda para cualquier efecto secundario que pueda tener?

¿Qué tipo de atención de seguimiento obtendré?

### Otras preguntas que debe considerar

¿Qué otra información necesito para decidir?

¿Participar en un grupo de apoyo me ayudará a tomar mi decisión?

¿Es conveniente esperar sabiendo que hay posibilidades que el cáncer crezca?

¿Cómo mi decisión afectará mis relaciones?

¿Con qué efectos secundarios puedo vivir?

¿Cómo afectarán mi vida sexual los efectos secundarios?

¿Me sentiré bien si ya no vuelvo a tener erecciones después del tratamiento del cáncer de próstata?

¿Cuánto tiempo, dinero, y apoyo necesito para la opción que yo elija?

### ¿Dónde puedo obtener más información?

Si desea más información sobre el tratamiento, investigación, y apoyo en relación con el cáncer de próstata, visite la página Web de Medline Plus: www.nlm.nih.gov/medlineplus/spanish/prostatecancer.html

Si desea más información sobre la detección del cáncer de próstata, visite la página Web de los Centers for Disease Control and Prevention: www.cdc.gov/spanish/cancer/prostate/decisionguidespotlight.htm

Si desea más información sobre el tratamiento y la investigación del cáncer de próstata, visite la página Web del National Cancer Institute: www.cancer.gov/espanol/tipos/necesita-saber/prostata

### ¿Dónde puedo obtener una copia de esta guía?

Para obtener una copia electrónica de esta guía y materiales sobre la elección de tratamientos y medicamentos para otros trastornos médicos, visite esta página Web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm (http://effectivehealthcare.ahrq.gov/index.cfm/guides-for-patients-and-consumers/informacion-en-espanol/)

Para obtener una copia gratuita, llame a: AHRQ Publications Clearinghouse, (800) 358–9295

Pida la publicación de AHRQ número 08(09)-EHC010-B6

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de informes de investigación. La revisión se titula Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer – 2008 (Comparación de la efectividad de tratamientos para el cáncer de próstata clínicamente circunscrito – 2008), y fue escrita por el Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Minnesota).

## Related Content

Research Review

Clinician Guide

Consumer Guide