# Progestágenos para prevenir el parto prematuro

Revisión de la investigación sobre el uso de progestágenos en las mujeres con riesgo

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Usted tuvo antes al menos un bebé prematuro debido a que el trabajo de parto empezó espontáneamente antes de las 37 semanas de embarazo (por ejemplo, a las 20 semanas). Es lo que se llama “parto prematuro espontáneo”. Un ejemplo es cuando se “rompe la fuente” antes de las 37 semanas de embarazo. Usted puede estar embarazada o está considerando volver a embarazarse.
- Su médico^*^ le ha dicho que tiene el cuello uterino corto. (El cuello uterino, o cérvix, es la abertura estrecha con forma tubular situada en la parte baja del útero. El útero, o matriz, es donde crece el bebé durante el embarazo).
- Su médico le ha dicho que usted corre el riesgo de tener un parto prematuro. Si no está segura si corre el riesgo de tener un parto prematuro, pregunte a su médico.
- Ha oído sobre el uso de unas hormonas llamadas “progestágenos” para evitar el parto prematuro y desea saber lo que dicen las investigaciones acerca de los beneficios y posibles efectos secundarios de este tratamiento.

### No es apropiada si

- Ya tiene 37 semanas o más de embarazo.
- Nunca ha tenido antes un bebé que haya nacido adelantado debido a un parto prematuro espontáneo.
- Está embarazada con más de un bebé; por ejemplo, mellizos o trillizos.

### ¿Qué aprenderé con este resumen?

Este resumen habla sobre el riesgo de tener un parto prematuro. También explica lo que dicen las investigaciones acerca de los beneficios y daños que puede causar el uso de un progestágeno para evitar un parto prematuro. Esta información le ayudará a hablar con su médico para saber si el uso de un progestágeno es la mejor opción de tratamiento para usted.

### ¿De dónde proviene la información?

La información de esta guía proviene de una revisión de 63 estudios de investigación sobre progestágenos. La revisión fue financiada por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal. El informe completo puede leerse en www.effectivehealthcare.ahrq.gov/pretermbirth.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es el parto prematuro espontáneo?

El parto prematuro es el parto que ocurre antes de las 37 semanas de embarazo (un embarazo de término completo dura entre 37 y 42 semanas). Cuando el parto prematuro se produce por sí solo, sin ser inducido por una razón médica específica, se le llama “parto prematuro espontáneo”.

Algunos bebés que nacen antes de las 37 semanas tienden a necesitar cuidados especiales. Tal vez necesitarán ser atendidos en una unidad de cuidados intensivos. Los bebés que nacen muy temprano corren un mayor riesgo de tener discapacidades o posiblemente de morir.

Más de 475,000 bebés, o alrededor de 12 por ciento de todos los partos anuales en Estados Unidos, son prematuros. Para la familia de cada uno de estos bebés, el parto prematuro puede causar gran aflicción y angustia, así como aumentar los costos de atención para la madre y el bebé.

### ¿Cuál es la diferencia entre el trabajo de parto pretérmino y el parto prematuro?

El trabajo de parto pretérmino significa que la mujer empieza a tener contracciones y que el cuello uterino comienza a ensancharse (dilatarse) antes de la semana 37 del embarazo. El trabajo de parto pretérmino puede tener como consecuencia un parto prematuro. No siempre es posible detener el trabajo de parto pretérmino una vez que inicia y muchos bebés nacen demasiado temprano.

Por esa razón, los médicos han estado buscando maneras de ayudar a las mujeres a evitar que inicien el trabajo de parto hasta que el embarazo llegue por lo menos a las 37 semanas.

### ¿Por qué corro el riesgo de tener un parto prematuro?

Los médicos han descubierto varias cosas que pueden hacer que una mujer corra el riesgo de tener un parto prematuro, entre ellas:

- Haber tenido un parto prematuro anteriormente
- Estar embarazada con más de un bebé, como por ejemplo, mellizos o trillizos
- Tener el cuello uterino corto (si la abertura estrecha y con forma tubular del útero tiene menos de una pulgada de largo)
- Tener algunos síntomas de trabajo de parto pretérmino, como contracciones tempranas que empiezan a abrir el cuello uterino

Su médico puede decirle si corre el riesgo de tener un parto prematuro.

## Conozca los progestágenos

### ¿Qué es el progestágeno?

Los progestágenos pueden ser de dos tipos:

- La hormona natural llamada progesterona, que fabrica su propio cuerpo
- Una hormona similar que se fabrica en un laboratorio (llamada “hormona sintética” o progestina)

La hormona progesterona que el cuerpo elabora ayuda a que el embarazo se produzca y se mantenga. El uso de progesterona natural o sintética (progestágenos) adicional puede ayudar a evitar el parto prematuro en algunas mujeres.

Los progestágenos se pueden administrar de varias formas:

- Como gel, crema, cápsulas o supositorios que usted coloca en la vagina
- Como inyección en el brazo u otros músculos
- Como pastillas que se toman (menos usual)

### ¿Qué dicen las investigaciones acerca del uso de progestágenos?

- Algunas investigaciones encontraron que los progestágenos ayudan a las mujeres que están embarazadas con un bebé y que tuvieron un parto prematuro en un embarazo anterior.
  - En 1 de cada 11 de estas mujeres que usan un progestágeno, el tratamiento ayudará a que el embarazo dure por lo menos 37 semanas.
  - Los progestágenos pueden también ayudar a estas mujeres a reducir el riesgo de que su bebé muera al nacer, pero no existe suficiente investigación para saberlo con certeza.
  - Si bien las tres formas de progestágenos (pastillas, inyecciones y gel o supositorios vaginales) pueden reducir el riesgo de tener un parto prematuro espontáneo, los médicos no pueden asegurar si una forma es más eficaz que la otra.
- Dos estudios de investigación mostraron que las mujeres con un cuello uterino corto y que se trataron con progestágenos tuvieron una menor probabilidad de tener un parto prematuro. No existe investigación suficiente para saber con certeza cuántas mujeres con cuello uterino corto podrían beneficiarse.
- Las mujeres embarazadas con mellizos o trillizos no obtuvieron ningún beneficio con el uso de progestágenos.
- No existe investigación suficiente para saber si los progestágenos pueden ayudar a evitar el parto prematuro en las mujeres con otros factores de riesgo, como trabajo de parto pretérmino (contracciones prematuras que abren el cuello uterino).

### ¿Qué tan seguros son los progestágenos?

No existe suficiente investigación sobre los efectos secundarios que causan los progestágenos para poder conocer sobre su seguridad en general. El efecto secundario a corto plazo más frecuente que tuvieron las mujeres en los estudios de investigación fue la sensación de molestia en el sitio de inyección o la irritación con el uso de las formas vaginales (por ejemplo, la crema o el gel). Los médicos desconocen si pueden ocurrir efectos secundarios a largo plazo después de meses o años de haber dado a luz.

## Tome una decisión

### ¿En qué cosas debo pensar?

Hay varias cosas que debe hablar con su médico o profesional de atención médica al decidir si un progestágeno es una buena opción para usted.

Hable con su médico sobre:

- Los beneficios de usar progestágenos para evitar el parto prematuro
- La incertidumbre sobre posibles efectos secundarios con el uso de un progestágeno
- Sus preferencias y estilo de vida
- El costo de las pastillas, inyecciones o supositorios de progestágeno

### ¿Qué tan cómoda se siente con lo que se conoce sobre los progestágenos?

Los médicos conocen más sobre cómo los progestágenos pueden ayudar, pero menos sobre sus posibles efectos secundarios a largo plazo. Es importante que hable con su médico sobre qué tan cómoda se siente con lo que se sabe sobre los beneficios y la seguridad del uso de progestágenos para evitar el parto prematuro.

### ¿Cómo afectará mi estilo de vida el uso de un progestágeno?

La prevención del parto prematuro puede afectar la cantidad de actividad o trabajo que usted puede hacer. Pero el progestágeno en sí no debe afectar su estilo de vida.

Los progestágenos en gel vaginal y en pastillas pueden administrarse en casa. Si va a usar una forma inyectable, necesitará ir al consultorio de su médico o profesional de atención médica una vez por semana o solicitar que venga a su casa una enfermera a inyectarle.

Su médico o profesional de atención médica puede elaborar un plan con usted.

### ¿Cuál es el costo?

El costo para usted de los progestágenos en cualquiera de sus formas depende de:

- La dosis (cantidad) que necesite
- La frecuencia con que deban administrarse
- La marca del producto que usted usa
- La cantidad de tiempo que tenga que usarlos
- Su plan de seguro médico
- Si compra un producto de marca comercial o uno genérico

Los progestrágenos en pastillas, geles vaginales e inyecciones existen todos en forma genérica. El costo más bajo puede ser entre $3 y $20 por dosis. El costo promedio de la forma más cara de la inyección de progestágeno puede ser de hasta $700.

Si una mujer se trata con la forma de gel vaginal de progestágeno (a partir de la semana 16 y hasta la semana 37 de embarazo), el costo total de 21 semanas de tratamiento puede oscilar entre $1,800 y $2,500, dependiendo de la marca del gel.

### Pregunte a su médico u otro profesional de atención médica

Hable con su médico o profesional de atención médica sobre el uso de progestágenos para evitar el parto prematuro. Estas son algunas preguntas que tal vez quiera hacer:

- ¿Usar un progestágeno podrá ayudarnos a mí y a mi bebé?
- De ser así, ¿qué forma de progestágeno sería la mejor para mí?
- ¿Qué piensa usted de las cosas que los médicos todavía desconocen sobre los progestágenos?
- ¿Qué más puedo hacer para ayudar a prevenir un parto prematuro?

#### Otras preguntas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

#### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Effectiveness of Progestogens for Prevention of Preterm Birth (Eficacia de los progestágenos para la prevención del parto prematuro) de agosto de 2012.

El informe fue producido por el Vanderbilt University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Vanderbilt), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/pretermbirth.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish. Los costos de los medicamentos incluidos en este resumen provienen de “A Guide to the Cost of Progesterone for Prevention of Preterm Labor” (Guía del costo de la progesterona para la prevención del trabajo de parto pretérmino), artículo publicado en el número del 15 de abril de 2011 de la revista especializada Proceedings in Obstetrics and Gynecology (Anales de obstetricia y ginecología). El artículo está disponible sólo en inglés en http://ir.uiowa.edu/pog/vol1/iss3/9.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. En la revisión de este resumen participaron mujeres embarazadas con riesgo de parto prematuro.

Esta guía fue traducida de la publicación en inglés titulada Progestogens To Prevent Preterm Birth: A Review of the Research About Progestogens for Women at Risk.

* En este resumen, el término “médico” se refiere a cualquier profesional de atención médica que pueda atenderla, lo que incluye su obstetra u otro médico, enfermera, partera o asistente médico.