# Medicamentos para la artritis psoriásica

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico^*^ le ha dicho que tiene artritis psoriásica (PsA, por su sigla en inglés).
  - Es un tipo de artritis que afecta a las personas que tienen psoriasis.
  - La psoriasis es una condición crónica de la piel que produce unas manchas rojas escamosas en el cuerpo.
- Su médico le ha sugerido tomar uno o más de los siguientes medicamentos antirreumáticos modificadores de la enfermedad (DMARD, por su sigla en inglés)^†^ para ayudar a tratar la PsA:
  - Adalimumab (Humira^®^)
  - Etanercept (Enbrel^®^)
  - Golimumab (Simponi^®^)
  - Infliximab (Remicade^®^)
  - Leflunomida (Arava^®^)
  - Metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^)
  - Sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^)
- Usted quiere saber qué dicen las investigaciones sobre la eficacia de estos medicamentos para tratar la PsA.

### No, esta información no es apropiada para usted si

- Tiene otro tipo de artritis, tal como la osteoartritis o la artritis reumatoide.
- Tiene psoriasis (la condición de la piel) pero no tiene PsA.
- Su médico no ha sugerido un DMARD para tratar la PsA.
- Tiene menos de 18 años de edad. Esta información proviene de investigación realizada en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen le informará sobre los DMARD, un tipo de medicamento para las personas con PsA. Mencionará también los posibles efectos secundarios de estos medicamentos. Le explicará lo que han descubierto las investigaciones sobre la eficacia de los DMARD para tratar la PsA. También puede ayudarle a hablar con su médico para saber si alguno de estos medicamentos puede ser apropiado para usted. Este resumen no analiza los tratamientos para la condición de la piel vinculada a la psoriasis.

Los DMARD se utilizan para tratar varias enfermedades que afectan al sistema inmunológico y mucho de lo que se sabe sobre los DMARD proviene de estudios de pacientes con artritis reumatoide o con psoriasis. El número de investigaciones con pacientes que tienen PsA y están tomando un DMARD, ha sido mucho menor.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 16 estudios acerca de los medicamentos para la artritis psoriásica publicados antes de enero de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/dmardspsa.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la artritis psoriásica?

La artritis psoriásica (PsA) es un tipo de artritis que afecta solamente a personas con psoriasis. La psoriasis es una condición crónica de la piel que produce unas manchas rojas escamosas en el cuerpo. La PsA causa dolor, hinchazón y rigidez en sus articulaciones. Menos personas padecen de PsA que de otros tipos de artritis.

- No todas las personas que tienen psoriasis desarrollan PsA, pero las que padecen psoriasis tienden más a desarrollar artritis que las que no tienen psoriasis.
- En la mayoría de los casos, la persona adquiere la psoriasis antes de desarrollar PsA.
- A menudo, los síntomas de la psoriasis empeoran al mismo tiempo en que se inician los síntomas de la artritis.
- La PsA suele ser leve, pero puede afectar muchas articulaciones.
- La PsA suele afectar las articulaciones de las puntas de los dedos de las manos o pies y luego extenderse para abarcar más articulaciones y huesos.
- La PsA grave puede causar deformidad de las articulaciones.

### ¿Qué causa la PsA?

Se desconoce la causa de la PsA, pero los investigadores piensan que la condición puede pasarse en las familias, de generación en generación. El dolor y los síntomas de la PsA ocurren cuando el sistema inmunológico de una persona (el sistema corporal que le ayuda a defenderse de los microbios) ataca el revestimiento sano de las articulaciones. Los médicos no saben con seguridad por qué el sistema inmunológico ataca las articulaciones en algunas personas. Los médicos tampoco saben cómo evitar que las personas con psoriasis adquieran PsA.

### ¿Qué tan frecuente es la PsA?

- Menos de 1 por ciento de los adultos en Estados Unidos tienen PsA.
- De cada 20 personas con psoriasis, 1 o más desarrollarán PsA.
- La PsA tiende más a desarrollarse en personas de 30 a 50 años de edad.

### ¿Cómo puede ayudar el tratamiento?

Aunque no hay cura para la PsA, el tratamiento puede:

- Aliviar el dolor y la hinchazón.
- Retardar o detener el daño a las articulaciones.
- Ayudar a reducir el número de “crisis” con los síntomas (momentos en que empeoran el dolor o la hinchazón).
- Mejorar su capacidad de realizar actividades diarias, como bañarse, vestirse, hacer tareas domésticas, extender los brazos y levantar objetos.

### ¿Qué medicamentos se usan para tratar la PsA?

La PsA se trata con varios tipos diferentes de medicamentos, incluidos:

- Analgésicos: Medicamentos sin receta, como aspirina, acetaminofén (Tylenol^®^), ibuprofeno (Advil^®^, Motrin^®^) o naproxeno (Aleve^®^).
- Corticoesteroides: Medicamentos que también pueden aliviar el dolor y la hinchazón de la PsA por un tiempo breve.
- Medicamentos antirreumáticos modificadores de la enfermedad (DMARD): Medicamentos que pueden disminuir los síntomas, retardar o detener el daño a las articulaciones y mejorar la capacidad de realizar las actividades diarias.

En este resumen, sólo se abordan las investigaciones relacionadas con los DMARD.

## Conozca los DMARD

### ¿Qué son los DMARD?

Los DMARD son una familia de medicamentos que impiden que el sistema inmunológico ataque y destruya las articulaciones. Si usted tiene síntomas graves de PsA o no obtiene alivio suficiente con los analgésicos o los corticoesteroides, tal vez su médico sugiera usar un DMARD. Los DMARD pueden tomarse juntos o con otros analgésicos o corticoesteroides.

Existen dos tipos de DMARD: los no biológicos y los biológicos.

#### DMARD no biológicos

Al igual que la mayoría de los medicamentos, los DMARD no biológicos se fabrican con sustancias químicas. Por lo general, se toman una vez al día o una vez a la semana en forma de pastillas, pero algunos pueden también inyectarse. Los DMARD no biológicos que se estudiaron en las investigaciones para este resumen son:

- Leflunomida (Arava^®^)
- Metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^)
- Sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^)

#### DMARD biológicos

Los DMARD biológicos son proteínas similares a las que el cuerpo produce, pero estas proteínas se fabrican en laboratorios. Los DMARD biológicos deben administrarse en forma de inyección o mediante un tubo intravenoso (IV) colocado en una vena del brazo. Los DMARD biológicos que se estudiaron en las investigaciones para este resumen son:

- Adalimumab (Humira^®^)
- Etanercept (Enbrel^®^)
- Golimumab (Simponi^®^)
- Infliximab (Remicade^®^)

El DMARD biológico infliximab (Remicade^®^) debe administrarse por medio de un tubo intravenoso (IV) en un consultorio médico o clínica. El procedimiento puede tardar hasta 2 horas. Otros DMARD biológicos vienen en forma de plumas inyectoras que puede usar en casa.

La mayoría de los DMARD biológicos se administran una vez al mes, cada dos semanas o cada semana. Su médico puede cambiar el plan, dependiendo de su mejoría.

### ¿Qué dicen las investigaciones acerca de los DMARD no biológicos?

Los investigadores descubrieron que el metotrexato (Folex^®^, Rheumatrex^®^, Trexall^®^), la sulfasalazina (Azulfidine EN-Tabs^®^, Sulfazine^®^) y la leflunomida (Arava^®^) parecen todos disminuir los síntomas de la PsA. Se necesitan más investigaciones para saber si alguno de estos medicamentos funciona mejor que los otros.

### ¿Qué dicen las investigaciones sobre los DMARD biológicos?

Los investigadores observaron que:

- El adalimumab (Humira^®^), el etanercept (Enbrel^®^) y el infliximab (Remicade^®^) disminuyen los síntomas de la PsA y mejoran la capacidad para realizar actividades.
- El golimumab (Simponi^®^) parece disminuir los síntomas de PsA y mejorar la capacidad para realizar actividades, pero no existe suficiente investigación para saberlo con certeza.
- El adalimumab, el etanercept, el golimumab y el infliximab parecen mejorar la calidad de vida, pero no existe suficiente investigación para saber qué tanto la mejoran. La calidad de vida es una medida para saber cómo la PsA afecta a la persona en su aspecto físico, emocional y social.
- Se necesitan hacer más investigaciones para saber si alguno de estos medicamentos funciona mejor que los otros.
- El uso de un DMARD biológico junto con el DMARD no biológico metotrexato, parece actuar con la misma eficacia que cuando se toma un DMARD biológico solo, pero no existe suficiente investigación para saberlo con certeza.

### Comparación entre los DMARD no biológicos y biológicos

No existen suficientes investigaciones que comparen los DMARD no biológicos con los biológicos para saber qué tipo de DMARD puede ser mejor para tratar la PsA.

### ¿Cuáles son los posibles efectos secundarios de los DMARD no biológicos y biológicos?

Debido a que los DMARD no biológicos y biológicos actúan de manera distinta, también tienen diferentes efectos secundarios, algunos de ellos graves.

Posibles efectos secundarios que causan los DMARD

DMARD no biológicos | DMARD biológicos
- Malestar estomacal; - Náuseas; - Diarrea; - Pérdida de cabello; - Úlceras en la boca; - Salpullido o reacciones graves en la piel; - Problemas del hígado, los riñones o los pulmones | - Enrojecimiento, hinchazón, comezón, moretones o dolor en la zona donde se aplicó la inyección; - Sinusitis (dolor de garganta, secreción nasal, ronquera); - Dolor de cabeza
Posibles efectos secundarios graves
- En casos raros, el DMARD no biológico metotrexato y algunos DMARD biológicos (incluidos adalimumab [Humira^®^], etanercept [Enbrel^®^], golimumab [Simponi^®^] e infliximab [Remicade^®^]) se han vinculado con:; - Infecciones graves, como la tuberculosis (llamada “TB”); infecciones por hongos, como la candidiasis; neumonía o enfermedades adquiridas por alimentos, como listeriosis; - Cáncer, por lo común linfoma (cáncer de los ganglios linfáticos, que son parte del sistema inmunológico); - El riesgo de infecciones graves o cáncer es mayor cuando se toman dos o más DMARD biológicos juntos o se toma un DMARD biológico junto con un DMARD no biológico. Se desconoce cuál es exactamente el riesgo que corren las personas con PsA que toman un DMARD.

Esta información proviene de las etiquetas de estos medicamentos aprobadas por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se necesitan más investigaciones para saber qué DMARD puede funcionar mejor en distintas personas. Deben considerarse varias cosas cuando se elija un medicamento para tratar su PsA:

- Hasta qué punto los beneficios compensan los efectos secundarios posibles de cada medicamento.
- Qué medicamento se adapta mejor a su estilo de vida, lo que usted considera importante (sus valores) y sus preferencias.
  - Tal vez quiera considerar si prefiere que el medicamento se administre en pastillas, inyecciones o por un tubo intravenoso. Tal vez quiera también considerar con qué frecuencia puede ir al consultorio o la clínica y cuánto tiempo tiene disponible para estar allí.
- El costo de cada medicamento.

### ¿Hasta qué punto los riesgos compensan los beneficios?

Solamente usted y su médico pueden decidir si el uso de cierto DMARD para tratar la PsA compensa el riesgo de los posibles efectos secundarios. Usted y su médico deben hablar acerca de:

- El grado de dolor o daño que tenga en las articulaciones y si el tratamiento con un DMARD puede ayudar
- El riesgo de padecer efectos secundarios graves a causa de los DMARD
- Signos a los que debe estar atento para detectar efectos secundarios graves, a fin de que puedan tratarse o se pueda cambiar el medicamento
- Otras opciones, además de los DMARD, que puedan aliviar su PsA

### ¿Cuáles son los costos?

Los costos para usted de los DMARD no biológicos y biológicos dependen de:

- Su plan de seguro médico
- La cantidad (dosis) que necesite
- Si el medicamento se puede administrar en pastillas, en inyecciones o por un tubo intravenoso
- Si existe una forma genérica del medicamento
- Si el laboratorio que fabrica el medicamento ofrece asistencia económica para reducir el costo

Precios de mayoreo: DMARD no biológicos y biológicos

Nombre del medicamento | Nombre comercial | Precio por mes^*^ | Forma | Dosis
DMARD no biológicos
Lefunomida | Genérico | $490 | Tableta | 20 mg al día
Lefunomida | Arava^®^ | $910 | Tableta | 20 mg al día
Metotrexato | Genérico | $45–$90 | Tableta | 7.5–15 mg por semana
Metotrexato | Folex^®^, Rheumatrex^®^, Trexall^®^ | $125–$140 | Tableta | 7.5–15 mg por semana
Sulfasalazina | Genérico | $40 | Tableta | 2,000 mg al día
Sulfasalazina | Azulfidine EN-Tabs^®^ | $120 | Tableta | 2,000 mg al día
Sulfasalazina | Sulfazine^®^ | $30 | Tableta | 2,000 mg al día
DMARD biológicos (no existen versiones genéricas de estos medicamentos)
Adalimumab | Humira^®^ | $2,450 | Inyección | 40 mg dos veces al mes
Etanercept | Enbrel^®^ | $2,475 | Inyección | 50 mg por semana
Golimumab | Simponi^®^ | $2,650 | Inyección | 50 mg al mes
Infliximab | Remicade^®^ | $3,725–$9,300 | IV | 200 a 500 mg dos veces al mes (según su peso)

* Los precios son los precios promedio de mayoreo según el RED BOOK Online^®^ redondeados a los $5 más cercanos. Los precios del medicamento genérico son el valor promedio de los precios publicados por los distintos fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los de la lista, dependiendo de su seguro médico y del fabricante al que compre su farmacia.

IV = vía intravenosa

### Pregunte a su médico

- ¿Cree usted que un DMARD puede ayudarme con la PsA?
- ¿A qué efectos secundarios graves debo prestar atención?
- ¿Hay otros medicamentos que pueda tomar para ayudar a reducir los síntomas y el daño a las articulaciones que causa la PsA?
- ¿En cuánto tiempo empezaré a sentirme mejor?
- ¿Afectarán los medicamentos para la PsA la condición de la piel causada por la psoriasis? Si es así, ¿cómo?
- ¿El medicamento que estoy tomando para la psoriasis afectará al medicamento para la PsA?
- ¿Hay algún medicamento menos costoso que pueda tomar?
- ¿Qué más puedo hacer para aliviar la PsA?

#### Otras preguntas para su médico

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

#### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Drug Therapy for Psoriatic Arthritis in Adults: Update of a 2007 Report (Tratamiento con medicamentos de la artritis psoriásica en adultos: actualización de un informe de 2007), publicado en abril de 2012.

El informe fue producido por RTI International–University of North Carolina Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Carolina del Norte–RTI International) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/dmardspsa.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Este servicio está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con artritis psoriásica.

Esta guía fue traducida de la publicación en inglés titulada Medicines for Psoriatic Arthritis: A Review of the Research for Adults.

* En este resumen, la palabra “médico” se refiere a los profesionales de la atención médica que puedan atenderlo, lo que incluye a su médico, reumatólogo, dermatólogo, enfermera o asistente médico.

† Existen otros DMARD aparte de los que se mencionan aquí. Los DMARD que se mencionan aquí son los que se estudiaron en las investigaciones para este resumen.