# Osteoartritis de la rodilla

Guía para adultos

## Hechos resumidos

- La osteoartritis no tiene cura.
- Mantenerse activo y bajar de peso son acciones que le ayudarán a sentirse mejor.
- Algunas personas necesitan tomar analgésicos para controlar el dolor y mantenerse activas.
- En general, la glucosamina y la condroitina no reducen el dolor ni mejoran el movimiento de la rodilla.
- Las inyecciones para lubricar las articulaciones (que no son lo mismo que las inyecciones de cortisona) por lo general no reducen el dolor ni mejoran el movimiento de la rodilla.
- La cirugía artroscópica de la rodilla por lo general no reduce el dolor ni mejora el movimiento de la rodilla.

## ¿Qué cubre esta guía?

Los tratamientos para la osteoartritis de la rodilla pueden ayudarle a reducir el dolor. Pueden también ayudarle a mantenerse activo. La mayoría de las personas encuentra un plan de tratamiento que les funciona. A menudo, lo que mejor funciona es una combinación de tratamientos.

Esta guía le ayudará a aprender sobre sus opciones. También le puede ayudar a encontrar un plan de tratamiento que le funcione. Esta guía presenta varias formas que pueden ayudarle a sentirse mejor. También cubre investigación sobre tratamientos que generalmente no son útiles.

## Osteoartritis de la rodilla

La osteoartritis afecta a menudo la articulación de la rodilla. Ocurre cuando se desgasta el cartílago de la articulación.

El cartílago es un tejido similar al caucho, presente en los extremos de los huesos, que facilita el movimiento de la articulación. En la osteoartritis, el cartílago se va destruyendo con el tiempo. La rodilla puede llegar a doler, ponerse rígida e hincharse.

La rodilla contiene una cantidad pequeña de líquido que lubrica el cartílago. También ayuda a acojinar la articulación. En la osteoartritis, este líquido no funciona correctamente, lo que dificulta mover las articulaciones.

## Tratamientos que ayudan

Es importante que cualquier persona que tenga osteoartritis de la rodilla se ponga activa y mantenga un peso saludable. Algunas personas puede que necesiten tomar también analgésicos para disminuir el dolor y mantenerse en movimiento.

### Volverse activo

El hacer ejercicio es una buena manera para mejorar su salud. Tal vez usted crea que el ejercicio no es bueno para la osteoartritis. Pero sí lo es. El estar más activo y mantenerse activo le puede ayudar a tener menos dolor y a moverse más fácilmente.

El caminar, nadar y el ejercicio aeróbico acuático son buenas opciones para las personas con osteoartritis. Hable con su médico o enfermera para preparar un plan de ejercicio que le funcione.

Tal vez su médico le recomiende fisioterapia también. La fisioterapia, o terapia física, es un programa de ejercicio especial que se hace bajo la dirección de un profesional capacitado. Los ejercicios le ayudarán a moverse y mantenerse flexible. También pueden ayudarle a reducir el dolor de la rodilla.

### Lograr el peso correcto

El bajar de peso puede contribuir a quitar la carga de las rodillas. Cada libra que pierda ayudará. El mantenerse en un peso saludable le ayudará a estar más activo y en movimiento.

### Analgésicos

Los medicamentos pueden ayudar a aliviar el dolor de la osteoartritis de la rodilla. Algunas personas necesitan tomar analgésicos (medicamentos contra el dolor) para mantenerse activas. Existen analgésicos que son útiles para la osteoartritis. Su médico o enfermera puede recomendarle medicamentos sin o con receta.

Si desea conocer más sobre cómo escoger medicamentos que alivian el dolor de la osteoartritis, la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ, por sus siglas en inglés) ha publicado otra guía que puede serle útil. La guía se titula Escogiendo medicamentos para el dolor por osteoartritis: Guía para el consumidor (2007) y puede obtenerse en esta página web: www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

## Tratamientos que en general no ayudan

Esta información proviene de una revisión de informes de investigación sobre tres tratamientos para la osteoartritis de la rodilla, financiada por el gobierno. La investigación indica que estos tratamientos generalmente no ayudan a las personas que tienen osteoartritis de la rodilla.

### Glucosamina y condroitina

La glucosamina y la condroitina son suplementos alimenticios. La gente los toma para ayudar a formar cartílago nuevo. La glucosamina y la condroitina no están regulados como medicamentos en Estados Unidos, así que su calidad puede variar. Sus efectos secundarios leves consisten en malestar estomacal, diarrea y dolor de cabeza.

Los estudios de investigación indican que más de la mitad de las personas con osteoartritis mejoran con el uso de glucosamina y condroitina. Tienen menos dolor y mejor movimiento. Pero en esos estudios ha mejorado también la misma cantidad de personas que no toman esos suplementos. Eso significa que la glucosamina o la condroitina no son la razón por lo que algunas personas mejoran.

### Inyecciones para la lubricación articular

Las inyecciones para la lubricación articular no son lo mismo que las inyecciones de cortisona. En este tratamiento, se inyecta en la articulación un material de tipo gel. Por lo común, se aplican de tres a cinco inyecciones en el transcurso de unas semanas. El método se llama también viscosuplementación.

Infección, dolor e hinchazón leves son posibles efectos secundarios de las inyecciones para la lubricación articular. Estos efectos secundarios duran poco y desaparecen sin tratamiento. Es raro, pero las inyecciones también pueden causar hinchazón y dolor que no desaparecen por sí solos. Esto ocurre aproximadamente en 2 de cada 100 personas tratadas con las inyecciones. De ocurrir, pueden necesitarse medicamentos u otro procedimiento.

En muchos estudios de investigación se ha comparado a personas que se tratan con estas inyecciones, con otras que no reciben este tratamiento. Esos estudios indican que la mayoría de las personas tratadas con estas inyecciones no mejoran mucho. En general, las inyecciones no reducen el dolor ni mejoran el movimiento de la rodilla.

### Cirugía artroscópica para la osteoartritis

La cirugía artroscópica de la rodilla es una cirugía menor. Los médicos introducen un instrumento flexible en la articulación de la rodilla. Luego enjuagan la articulación. A veces alisan el cartílago y retiran fragmentos sueltos. Puede que ocurran problemas después de la operación tales como, dolor, hinchazón e infección. También pueden producirse coágulos en las piernas.

La investigación indica que la cirugía artroscópica por lo general no reduce el dolor de la osteoartritis de la rodilla. Los médicos pueden utilizar la cirugía artroscópica para tratar otros tipos de problemas de la rodilla, como lesiones deportivas. A veces es útil para esos problemas, pero no para la osteoartritis de la rodilla.

## Cosas que debe considerar

### ¿Estoy haciendo la cantidad correcta de ejercicio?

- El aumentar un poco la actividad unas veces por semana puede mejorar su resistencia y ayudar con los síntomas de la osteoartritis.
- La meta es mejorar el movimiento articular. El ejercicio no necesita ser difícil. Lo importante es ponerse en movimiento.
- Encuentre un tipo de ejercicio acorde con su estilo de vida.

### ¿Cómo puedo aprovechar al máximo las visitas al médico?

- Planee la visita, anotando lo que desea hablar.
- Asegúrese que su médico o enfermera conocen todos los medicamentos, vitaminas y suplementos que está tomando.
- Lleve una lista con las preguntas que quiere hacer.

### ¿Qué debo preguntarle a mi médico o enfermera?

- ¿Qué tan mal está mi osteoartritis de la rodilla?
- ¿Qué opciones existen para reducir mi dolor de rodilla?
- ¿Cómo me ayudará este tratamiento?
- ¿Cómo sabré si el tratamiento está funcionando?
- ¿Cuáles son todos los posibles efectos secundarios?

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía y materiales sobre la elección de tratamientos y medicamentos para otras condiciones, visite esta página web: www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Para obtener un ejemplar impreso gratuito llame a:

AHRQ Publications Clearinghouse (800) 358-9295

Pida la Publicación de AHRQ Número 09(10)-EHC001-B.

Si desea mayor información sobre la osteoartritis, visite la página web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/osteoarthritis.html.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 86 informes de investigación. Esa revisión se titula Treatment of Primary and Secondary Osteoarthritis of the Knee (Tratamiento de la osteoartritis primaria y secundaria de la rodilla) (2008) y fue escrita por el Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro de Evaluación Tecnológica de la Asociación Blue Cross y Blue Shield).

## Related Content

Research Review

Clinician Guide

Consumer Guide