# Tratamiento con medicamentos para el dolor por osteoartritis

Revisión de la investigación para adultos

## ¿Es este resumen apropiado para mí?

### Es apropiado si

- Un médico^*^ le dijo que usted tiene osteoartritis. La osteoartritis es diferente de otros tipos de artritis, como la artritis reumatoide o la psoriásica.
- El médico le recomendó uno de los medicamentos siguientes para el dolor por osteoartritis y usted quiere saber lo que dicen las investigaciones acerca del medicamento.
  - Acetaminofén (Tylenol^®^)
  - Ibuprofeno (Motrin^®^, Advil^®^)
  - Diclofenaco (Cambia^®^, Cataflam^®^, Voltaren^®^, Voltarol^®^, Zipsor^®^)
  - Naproxeno (Aleve^®^, Naprosyn^®^)
  - Celecoxib (Celebrex^®^)
  - Etodolaco (Lodine^®^)
  - Meloxicam (Mobic^®^)
  - Nabumetona (Relafen^®^)
  - Aspirina
- Está considerando tomar los suplementos alimenticios glucosamina o condroitina, para su dolor por osteoartritis.

### No es apropiado si

- Un médico no le ha dicho que usted tiene osteoartritis.
- Usted tiene menos de 18 años de edad. La información de este resumen proviene de investigaciones en adultos.

### ¿Qué cubre este resumen?

Este resumen explica cómo tratar el dolor por osteoartritis utilizando un grupo de medicamentos llamados “analgésicos”. También habla de las investigaciones acerca de diversos tipos de analgésicos. Explica la capacidad que tiene cada medicamento para aliviar el dolor y los riesgos de que cause efectos secundarios graves. También puede ayudarle a hablar con su médico acerca del tratamiento para el dolor por osteoartritis. El resumen no incluye otras formas de controlar el dolor por osteoartritis, como la cirugía, los medicamentos narcóticos o los esteroides.

### ¿De dónde proviene la información?

Un grupo de investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés), una agencia del gobierno federal, actualizó una revisión de la investigación sobre el uso de analgésicos para la osteoartritis. La revisión actualizada incluyó 273 estudios de investigación publicados entre enero de 2005 y enero de 2011. El informe fue revisado por médicos clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/analgesicsupdate.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la osteoartritis?

La osteoartritis es una condición dolorosa que ocurre cuando las articulaciones se inflaman y se ponen rígidas.

- El cartílago es el tejido blando que está entre los huesos que se unen en una articulación. Actúa como amortiguador y permite que los huesos que se conectan puedan moverse fácilmente y sin frotarse.
- En las personas con osteoartritis, el cartílago que separa los huesos comienza a degradarse y los huesos empiezan a rozar entre sí.
- La osteoartritis causa daño, dolor e inflamación en la articulación.

#### ¿Qué tan frecuente es la osteoartritis?

- La osteoartritis es la forma más común de artritis.
- Afecta a cerca de 27 millones de personas en Estados Unidos.
- Es la causa principal de discapacidad.
- La osteoartritis es más frecuente en las personas de mayor edad, con sobrepeso o que se han lesionado una articulación.

#### ¿Por qué se trata el dolor de la osteoartritis?

- La osteoartritis puede ser muy dolorosa y puede empeorar con el tiempo.
- La osteoartritis puede causar dificultad para moverse, trabajar o disfrutar de las actividades.

## Conozca sus opciones

### ¿Qué significa controlar el dolor?

La osteoartritis no tiene cura. Sin embargo, su médico puede sugerir una o más de las siguientes acciones para ayudarle a controlar el dolor:

- Tomar medicamentos llamados analgésicos para aliviar el dolor y la inflamación.
- Mantener su peso en un nivel saludable para disminuir el impacto en sus articulaciones.
- Ejercitarse para reducir el dolor y facilitar las labores diarias.

#### ¿Qué son los analgésicos?

Los analgésicos son un tipo de medicamento que ayuda a aliviar el dolor y la inflamación. Los analgésicos se presentan en distintas formas:

- Acetaminofén: la mayoría de la gente conoce este medicamento por el nombre comercial Tylenol^®^.
- Medicamentos antiinflamatorios no esteroides (también llamados NSAID, por su sigla en inglés): tal vez conozca algunos de los nombres comerciales de estos medicamentos, como Advil^®^, Motrin^®^, Aleve^®^ y Celebrex^®^.
- Cremas para la piel: algunos nombres comerciales comunes son: BenGay^®^, Aspercreme^®^ o Theragen^®^.
- Suplementos: algunas personas usan los suplementos alimenticios glucosamina y condroitina para disminuir el dolor por osteoartritis.

Analgésicos para el dolor por osteoartritis

Acetaminofén
¿Cuáles son los nombres genéricos y los comerciales? | El nombre genérico de este medicamento es acetaminofén. El nombre comercial es Tylenol^®^.
¿Este medicamento puede comprarse sin receta? | Sí, este medicamento puede comprarse sin receta.
¿Qué tanto alivia el dolor y la inflamación este medicamento? | - Las investigaciones indican que este medicamento no reduce el dolor tanto como los NSAID.; - Este medicamento no reduce la inflamación.
¿Qué efectos secundarios puede causar este medicamento? | - Este medicamento puede dañar el hígado si se toma en cantidad excesiva o si se usa junto con bebidas alcohólicas.
NSAID
¿Cuáles son los nombres genéricos y los comerciales? | Estos medicamentos tienen muchos nombres genéricos y comerciales:
¿Cuáles son los nombres genéricos y los comerciales? | - Ibuprofeno; - Motrin^®^; - Advil^®^ | - Diclofenaco; - Cambia^®^; - Cataflam^®^; - Voltaren^®^; - Voltarol^®^; - Zipsor^®^ | - Naproxeno; - Aleve^®^; - Naprosyn^®^; - Celecoxib; - Celebrex^®^ | - Etodolaco; - Lodine^®^; - Meloxicam; - Mobic^®^
¿Algunos de estos medicamentos pueden comprarse sin receta? | El ibuprofeno y el naproxeno pueden comprarse sin receta.
¿Qué tanto alivian el dolor y la inflamación estos medicamentos? | - Todos estos medicamentos son prácticamente igual de eficaces para aliviar el dolor y la inflamación.; - Las investigaciones indican que todos estos medicamentos reducen el dolor mejor que el acetaminofén.; - El diclofenaco en crema para la piel funciona igual de bien que las pastillas de NSAID.
¿Qué efectos secundarios pueden causar estos medicamentos? | - Todos estos medicamentos pueden causar problemas serios del estómago, como sangrado o úlceras. Una mayor cantidad de personas han tenido esos problemas con los siguientes NSAID:
¿Qué efectos secundarios pueden causar estos medicamentos? | - Naproxeno | - Ibuprofeno | | - Diclofenaco
¿Qué efectos secundarios pueden causar estos medicamentos? | - El sangrado del estómago fue más frecuente en las personas que tomaron naproxeno que en las que tomaron ibuprofeno.; - Todos los NSAID, excepto el naproxeno, pueden aumentar la probabilidad de tener problemas del corazón.
Cremas para la piel
¿Cuáles son los nombres genéricos y los comerciales? | - NSAID; - Diclofenaco (Voltaren^®^); - Ibuprofeno | - Capsaicina; - Theragen^®^; - Zostrix^®^; - Capsagel^®^; - Salonpas-Hot^®^ | | - Salicilato; - Aspercreme^®^; - BenGay^®^; - Sportscreme^®^
¿Algunos de estos medicamentos pueden comprarse sin receta? | Las cremas de capsaicina y de salicilato pueden comprarse sin receta.
¿Qué tanto alivian el dolor y la inflamación estos medicamentos? | - Se redujo el riesgo de tener problemas graves del estómago en las personas que usaron un NSAID en crema en vez de pastillas, pero aumentó el de tener sequedad de la piel, irritación y comezón.; - El diclofenaco en crema para la piel funciona igual de bien que las pastillas de NSAID.; - Algunas investigaciones indican que la capsaicina puede aliviar el dolor con igual eficacia que los NSAID, y que no pasa lo mismo con el salicilato, pero no existe suficiente investigación para poder afirmarlo.
¿Cuáles son los efectos secundarios que pueden causar estos medicamentos? | - Los NSAID en crema pueden causar sequedad de la piel, irritación y comezón.; - La capsaicina puede causar una sensación leve de ardor las primeras veces que se usa.
Suplementos
¿Cuáles son los nombres genéricos y los comerciales? | Los nombres genéricos de estos suplementos son glucosamina y condroitina. Estos suplementos se venden con muchos nombres comerciales y a veces se venden combinados en una sola pastilla.
¿Estos suplementos pueden comprarse sin receta? | Sí, se venden sin receta y pueden encontrarse en supermercados, farmacias y tiendas de alimentos naturistas.
¿Qué tanto ayudan estos suplementos a reducir el dolor y la inflamación? | - Es posible que alivien el dolor tan bien como las pastillas de NSAID, pero no existe suficiente investigación para poder afirmarlo.
¿Qué efectos secundarios pueden causar estos suplementos? | - No existe suficiente investigación para saber si estos suplementos causan efectos secundarios.; - Los suplementos que se venden en Estados Unidos no están regulados por la Food and Drug Administration (Administración de Alimentos y Medicamentos de Estados Unidos, FDA por su sigla en inglés). Eso significa que la calidad de la glucosamina y de la condroitina puede variar y que el contenido puede ser diferente del que se indica en el envase. Los suplementos que se han estudiado han sido fórmulas con una pureza de 99%, sin ingredientes agregados, que no están disponibles en Estados Unidos. Eso significa que los suplementos que usted compre pueden no ser los mismos que los que se investigaron.

#### Más información sobre los efectos secundarios graves que puede causar un NSAID

Problemas del estómago: los investigadores encontraron que:
- La aparición de úlceras (llagas abiertas) en el estómago fue más frecuente en las personas que tomaban naproxeno, ibuprofeno o diclofenaco que en las que tomaban celecoxib, meloxicam o etodolaco.
- Más personas que tomaban naproxeno tuvieron problemas serios del estómago, como sangrado y úlceras, que las que tomaban ibuprofeno.
- En las personas que han tomado un NSAID y han tenido sangrado estomacal antes es más probable que un NSAID cause sangrado del estómago, que en las personas que no habían tenido este problema en el pasado.
- Las personas que toman diluyentes de la sangre (como Coumadin^®^ o warfarina) u otros medicamentos que evitan la coagulación (como la aspirina), cuando están tomando también naproxeno, ibuprofeno o diclofenaco, tienen una probabilidad de 3 a 6 veces mayor de tener sangrado estomacal, comparadas con las personas que solamente toman los diluyentes de la sangre.
- Las personas que toman una dosis (cantidad) pequeña de aspirina cuando están tomando también celecoxib, naproxeno, ibuprofeno o diclofenaco, aumentan su riesgo de tener úlcera aproximadamente en un 6 por ciento.
- Las personas que toman dosis altas de naproxeno, ibuprofeno o diclofenaco tienden más a tener sangrado del estómago que las que toman dosis bajas.
- El riesgo de tener problemas del estómago por el uso de un NSAID aumenta con la edad.
- El añadir celecoxib a un medicamento reductor del ácido estomacal (llamado inhibidor de la bomba de protones, o PPI, por su sigla en inglés) podría reducir el riesgo de que ocurran úlceras y sus complicaciones, incluido el sangrado.

Problemas del corazón: los investigadores encontraron que:
- El uso de celecoxib, ibuprofeno o diclofenaco aumenta la posibilidad de tener problemas del corazón.
- El naproxeno no aumenta el riesgo de ataque al corazón.
- En las personas que toman dosis altas de celecoxib, el riesgo de sufrir un ataque al corazón es mayor que en las que toman dosis bajas.
- El riesgo de tener problemas del corazón por el uso de los NSAID aumenta con la edad.
- Todos los NSAID pueden empeorar la presión arterial, la función del corazón y la función del riñón. Sin embargo, no hay diferencias claras entre naproxeno, ibuprofeno, diclofenaco, etodolaco, meloxicam o nabumetona, en cuanto al riesgo de tener presión arterial alta, insuficiencia cardiaca o función deficiente del riñón.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Cada medicamento contra el dolor tiene un conjunto diferente de beneficios y riesgos, y cada uno tiene ventajas y desventajas. Hable con su médico para sopesar los beneficios y los riesgos y para decidir qué medicamento es el mejor para usted. Hable con su médico acerca de:

- Cuánto dolor e inflamación siente y cada cuánto los siente.
- La eficacia de cada medicamento para aliviar el dolor y la inflamación.
- Qué tanto les preocupen a usted y a su médico los riesgos de tener efectos secundarios graves.
- Su edad u otros problemas de salud que puedan influir en su elección del medicamento para el dolor.
- La conveniencia y el costo de que hayan medicamentos con o sin receta.

### ¿Qué costo tienen los analgésicos?

El costo de los analgésicos para usted depende de:

- El tipo de seguro médico que tenga.
- La dosis (cantidad) que necesite.
- Si existe el medicamento en forma genérica o si se vende sin receta. Algunos NSAID pueden comprarse sin receta, pero es posible que su seguro no cubra el costo si los compra de esta forma.

El costo de los analgésicos sin receta depende de la farmacia, el nombre del medicamento y la cantidad que se compre en el momento. Cuando busque dónde obtener el costo más bajo, tome en cuenta también la calidad del producto.

Costos de mayoreo de los analgésicos con receta

Nombre del medicamento | Dosis | Forma | Cada cuánto | Precio del genérico, mensual^*^ | Nombre comercial | Precio de la marca comercial, mensual^*^
NSAID
Celecoxib | 100 mg | Tableta | Dos veces al día | ND | Celebrex^®^ | $176
Celecoxib | 200 mg | Tableta | Una vez al día | ND | Celebrex^®^ | $145
Ibuprofeno | 400 mg | Tableta | Tres veces al día | $18 | Motrin^®^; Advil^®^ | $28; $10
Ibuprofeno | 400 mg | Tableta | Cuatro veces al día | $25 | Motrin^®^; Advil^®^ | $37; $13
Ibuprofeno | 600 mg | Tableta | Tres veces al día | $26 | Motrin^®^; Advil^®^ | $36; $15
Ibuprofeno | 600 mg | Tableta | Cuatro veces al día | $35 | Motrin^®^; Advil^®^ | $48; $20
Ibuprofeno | 800 mg | Tableta | Tres veces al día | $35 | Motrin^®^; Advil^®^ | $51; $20
Ibuprofeno | 800 mg | Tableta | Cuatro veces al día | $46 | Motrin^®^; Advil^®^ | $68; $27
Diclofenaco | 50 mg | Tableta | Dos veces al día | $93 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $1,547,
Diclofenaco | 50 mg | Tableta | Dos veces al día | $93 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $290;
Diclofenaco | 50 mg | Tableta | Dos veces al día | $93 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $344
Diclofenaco | | | Tres veces al día | $140 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $2,320;
Diclofenaco | | | Tres veces al día | $140 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $435;
Diclofenaco | | | Tres veces al día | $140 | Cambia^®^; Cataflam^®^; Zipsor^®^ | $516
Naproxeno | 250 mg | Tableta | Dos veces al día | $47 | Aleve^®^; Naprosyn^®^ | ND; $97
Naproxeno | 375 mg | Tableta | Dos veces al día | $64 | Aleve^®^; Naprosyn^®^ | ND; $124
Naproxeno | 500 mg | Tableta | Dos veces al día | $78 | Aleve^®^; Naprosyn^®^ | ND; $151
Etodolaco | 300 mg | Tableta | Dos veces al día | $86 | Lodine^®^ | $101
Etodolaco | 300 mg | Tableta | Tres veces al día | $128 | Lodine^®^ | $152
Etodolaco | 400 mg | Tableta | Dos veces al día | $88 | Lodine^®^ | $107
Etodolaco | 500 mg | Tableta | Dos veces al día | $89 | Lodine^®^ | $108
Meloxicam | 7.5 mg | Tableta | Una vez al día | $95 | Mobic^®^ | $156
Meloxicam | 15 mg | Tableta | Una vez al día | $144 | Mobic^®^ | $239
Nabumetona | 500 mg | Tableta | Dos veces al día | $78 | Relafen^®^ | $126
Nabumetona | 1,000 mg | Tableta | Una vez al día | $78 | Relafen^®^ | $126
Nabumetona | 1,000 mg | Tableta | Dos veces al día | $156 | Relafen^®^ | $252
Nabumetona | 2,000 mg | Tableta | Una vez al día | $156 | Relafen^®^ | $252

* Los precios son el promedio de los precios de mayoreo que registra el RED BOOK Online^®^.

Los precios del medicamento genérico son el promedio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = no disponible

### Pregunte a su médico

- ¿Qué analgésico considera más seguro para mí, pero que me ayude a controlar el dolor?
- ¿Hay riesgo de que tenga problemas del estómago o el corazón si tomo un NSAID?
- ¿Cuanto tiempo tardará en aliviar mi dolor?
- ¿A qué efectos secundarios debo estar atento?
- ¿Es posible que mis otros problemas de salud o medicamentos influyan en el medicamento que debo tomar para aliviar el dolor por osteoartritis?
- ¿Qué otras opciones tengo si estos medicamentos no me ayudan?
- ¿Hay algo más que pueda hacer para ayudar a aliviar mi dolor por osteoartritis?

Otras preguntas para su médico:

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

Anote aquí las respuestas:

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

____________________________________________________________

## Fuente

La información de este resumen proviene del informe Analgesics for Osteoarthritis: An Update of the 2006 Comparative Effectiveness Review (Analgésicos para la osteoartritis: actualización de la revisión del 2006 de la eficacia comparada), octubre de 2011.

El informe fue producido por el Oregon Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Oregon), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés).

Para obtener una copia del informe o mayor información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/analgesicsupdate.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web de MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página web puede verse en español en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con osteoartritis.

Traducido de la publicación en inglés titulada Managing Osteoarthritis Pain With Medicines: A Review of the Research for Adults.

* En este resumen, la palabra “médico” se refiere a los profesionales de la atención médica que puedan atenderlo, lo que incluye a su médico, reumatólogo, enfermera o asistente médico.