# Escogiendo medicamentos para el dolor por osteoartritis

Guía para el consumidor

## Hechos resumidos

- El acetaminofén (Tylenol^®^) funciona para el dolor leve y ofrece menos riesgos que otras pastillas para el dolor.
- Las pastillas por prescripción (℞) para el dolor puede que funcionen mejor que las pastillas para el dolor sin prescripción médica (OTC, por sus siglas en inglés). Éstas también tienen una mayor posibilidad de ocasionar problemas serios como sangramiento estomacal y ataques al corazón.
- Las pastillas NSAID (medicamentos antiinflamatorios sin esteroides), como el ibuprofeno (Motrin^®^, Advil^®^), naproxeno (Aleve^®^) o la aspirina, reducen el dolor, pero pueden causar sangramiento estomacal. Usted puede reducir su riesgo tomando la menor dosis que pueda por el tiempo más corto que le sea posible.
- La aspirina puede causar sangramiento estomacal inclusive en dosis pequeñas.
- La crema de cuerpo de capsaicina, como Theragen^®^ y Zostrix^®^, puede ayudarle con el dolor leve. La crema de capsaicina también trae menos riesgos que las pastillas para el dolor.
- Las cremas para el cuerpo de salicilato, tales como Aspercreme^®^ o Bengay Arthritis^®^ no funcionan para el dolor de la osteoartritis.

## ¿Qué cubre esta guía?

Esta guía puede ayudarle a trabajar conjuntamente con su médico o enfermera para escoger medicamentos para alivio del dolor de la osteoartritis.

- Describe los diferentes tipos de medicamentos para alivio del dolor.
- También ofrece información sobre las concesiones que se reciben a cambio entre, el alivio del dolor, riesgos de problemas y el precio de los medicamentos.

Esta guía está basada en una revisión de investigación, auspiciada por el gobierno, de los medicamentos para alivio del dolor de la osteoartritis. Ésta incluye los medicamentos sin prescripción médica (OTC, por sus siglas en inglés) y algunos medicamentos por prescripción (℞).

Cada uno de los medicamentos en esta guía trae consigo beneficios y riesgos.

- Del lado positivo, reducen el dolor y la hinchazón. También pueden ayudarle a mantenerse activo.
- Del lado negativo, pueden causar sangramiento estomacal o aumentar sus posibilidades de un ataque al corazón.

Las personas actúan diferente en la forma que pesan los riesgos y beneficios. Algunas personas sienten que un pequeño aumento en el riesgo de padecer de un ataque al corazón está bien, si pueden obtener el alivio que necesitan para el dolor. Otras personas puede que no prefieran este tipo de concesión.

Esta guía puede ayudarle a aprender sobre los beneficios y riesgos de los medicamentos para alivio del dolor de la osteoartritis. El conocer los riesgos y beneficios puede ayudarle a decidir lo que es mejor para usted.

## ¿Qué no está cubierto?

Esta guía no incluye todas las formas para reducir el dolor causado por la osteoartritis. El ejercicio, bajar de peso, acupuntura, y cirugía, son otras formas para ayudarle a sentirse mejor y mantenerse activo. La guía tampoco cubre medicamentos opiáceos por prescripción como la morfina, Tylenol-3^®^, y Vicodin^®^.

## Comprenda los beneficios de los medicamentos para el dolor sin prescripción (OTC, por sus siglas en inglés)

### Acetaminofén (Tylenol^®^)

- La mayoría de las personas pueden tomar acetaminofén (Tylenol^®^) sin problema, mientras que sigan las instrucciones de la botella.
- Las investigaciones demuestran que el acetaminofén (Tylenol^®^) reduce el dolor leve, pero probablemente no ayuda con la inflamación o hinchazón.

### NSAIDs (medicamentos antiinflamatorios sin esteroides) sin prescripción

- Los medicamentos antiinflamatorios sin esteroides se conocen como NSAIDs (se pronuncia “EN-seds”, por sus siglas en inglés). Estos incluyen la aspirina, ibuprofeno (Advil^®^, Motrin^®^), y naproxeno (Aleve^®^). Estas pastillas funcionan bloqueando las enzimas del dolor.
- Las investigaciones demuestran que los NSAIDs reducen el dolor causado por la hinchazón. También ofrecen un alivio general del dolor.
- La aspirina también es un NSAID, pero no existe suficiente investigación sobre el uso de la aspirina para el dolor causado por la osteoartritis.

Advertencia—

Si usted alguna vez ha tenido sangramiento estomacal, presión alta, ataques al corazón, problemas del hígado o de los riñones, usted se encuentra en un alto riesgo de tener problemas serios. Hable con su médico o enfermera antes de tomar cualquier medicamento para el dolor.

### Glucosamina y condroitina

- La glucosamina y la condroitina son suplementos. No están reguladas como medicamentos en los Estados Unidos, por lo tanto su calidad puede variar. No existe forma de estar seguro que los suplementos que usted consigue en la tienda son tan buenos como los que se utilizan en los estudios de investigación.
- Las investigaciones demuestran que la combinación de glucosamina hidroclorida más el sulfato de condroitina pueden reducir dolores de moderados a severos, sin causar serios problemas.

### Cremas de cuerpo

- Las cremas de capsaicina como Zostrix^®^ y Theragen^®^ están hechas a base de pimentones picantes. Las investigaciones demuestran que reducen el dolor leve. Cinco de cada 10 personas que la utilizan sienten una sensación tibia, picazón, o ardor. La sensación de ardor desaparece con el tiempo.
- La crema de salicilato incluye el Aspecreme^®^ y Bengay Arthritis^®^. Las investigaciones demuestran que la crema de salicilato no funciona para el dolor de la osteoartritis.

## Comprenda los beneficios de las pastillas para el alivio del dolor por prescripción (℞)

Las pastillas para el dolor por prescripción incluyen NSAIDs con composición por prescripción y opiáceos (morfina, Tylenol-3^®^, Vicodin^®^). Esta guía no cubre los opiáceos. Existen tres clases de pastillas NSAID por prescripción:

### Pastillas NSAID tradicionales por prescripción

- Estas son las pastillas por prescripción tales como el ibuprofeno (Motrin^®^), diclofenaco (Voltaren^®^) e indometacina (Indocin^®^).
- Las pastillas NSAID por prescripción son más fuertes y muchas veces cuestan más que las de NSAID sin prescripción médica.
- Las investigaciones demuestran que reducen el dolor y la hinchazón.

### Inhibidores de COX-2

- El celecoxib (Celebrex^®^) es un tipo de NSAID llamado inhibidor de COX-2. Sirve para aliviar el dolor al igual que lo hacen otros NSAIDs.
- Los estudios de investigación a corto plazo han encontrado que el celecoxib (Celebrex^®^) es más seguro en el estómago que otras pastillas NSAID.
- Los otros dos inhibidores de COX-2 (Vioxx^®^ y Bextra^®^) fueron sacados del mercado en el 2005 debido a que presentaban un alto riesgo de causar ataques al corazón.

### Salicilatos

- Los salicilatos son pastillas NSAID por prescripción, tales como el salsalato (Disalcid^®^).
- No sabemos como los salicilatos se comparan con otros medicamentos para alivio del dolor de la osteoartritis, ya que existen muy pocas investigaciones.

## Comprenda el riesgo de tener problemas

### ¿Cual es el riesgo de ataque al corazón?

Las NSAIDs pueden aumentar la posibilidad de un ataque al corazón. Por cada 10,000 personas que toman NSAIDs, 30 de ellos tendrán un ataque al corazón que no hubiesen tenido, de no haber estado tomando NSAIDs. Las investigaciones recientes encontraron que:

- Algunos NSAIDs aumentan la posibilidad de un ataque al corazón:
- Celecoxib (Celebrex^®^).
- Ibuprofeno (Motrin^®^) en dosis altas (800 mg tres veces al día).
- Diclofenaco (Voltaren^®^) en dosis altas (75 mg dos veces al día).
- Naproxeno (Aleve^®^, Naprosyn^®^) no aumenta la posibilidad de un ataque al corazón.
- No sabemos que tan seguido otros NSAIDs se comparan cuando se trata de la posibilidad de un ataque al corazón.

### ¿Y qué sobre el riesgo al hígado?

Los problemas del hígado son raros con el acetaminofén (Tylenol^®^) y las otras pastillas para el dolor descritas en esta guía. Sin embargo, tomar mucho acetaminofén (Tylenol^®^) puede conllevar a tener problemas del hígado. Asegúrese de seguir las instrucciones en la botella. Tenga en mente que otros medicamentos contienen acetaminofén (Tylenol^®^). Asegúrese de verificar las etiquetas para que no tome demasiado.

### ¿Y qué sobre el riesgo a los riñones?

El riesgo es bajo, pero todas las pastillas NSAID y el acetaminofén (Tylenol®) pueden causar o empeorar la presión alta y los problemas con los riñones. Dos de cada 1000 personas dejan de tomar su medicamento debido a problemas con los riñones.

## Comprenda el riesgo de tener problemas

### ¿Cuál es el riesgo de tener sangramiento estomacal con las pastillas NSAID?

Todas las pastillas NSAID, incluyendo la aspirina, bloquean las enzimas que protegen el estómago. Esto puede causar sangramiento estomacal. No es posible predecir el riesgo de ninguna persona. Las investigaciones no pueden decirnos por cuánto tiempo usted puede utilizar pastillas NSAID sin sangrar. En general, el sangramiento estomacal es más probable en las personas que toman NSAIDs y que:

- Son mayores, especialmente más de 75 años de edad.
- Toman dosis más altas.
- Utilizan NSAIDs por tiempos más prolongados.
- También toman medicamentos para prevenir coágulos de sangre, como la aspirina o warfarina (Coumadin^®^).

### ¿Cuáles son las señales de sangramiento estomacal?

Llame a su médico o enfermera de inmediato si:

- Vomita sangre.
- Ve sangre en sus heces o si sus heces son de color negro o pegajosas como el alquitrán.
- Se siente bien débil.

### ¿Y qué si he tenido en el pasado sangramiento estomacal?

Si usted alguna vez ha tenido sangramiento estomacal, no tome ninguna pastilla NSAID, incluyendo aspirina. Si su médico o enfermera le recomienda pastillas NSAID, asegúrese de decirle que usted ha tenido sangramiento estomacal en el pasado.

Las personas de más edad que toman pastillas NSAID tienen un mayor riesgo de sangramiento estomacal

Para las personas de 16–44 años:

5 de cada 10,000 personas que toman NSAIDs tendrán un sangramiento serio

1 de cada 10,000 personas que toman NSAIDs morirán por un sangramiento

Para las personas de 45–64 años:

15 de cada 10,000 personas que toman NSAIDs tendrán un sangramiento serio

2 de cada 10,000 personas que toman NSAIDs morirán por un sangramiento

Para las personas de 65–74 años:

17 de cada 10,000 personas que toman NSAIDs tendrán un sangramiento serio

3 de cada 10,000 personas que toman NSAIDs morirán por un sangramiento

Para las personas de 75 años o mayores:

91 de cada 10,000 personas que toman NSAIDs tendrán un sangramiento serio

15 de cada 10,000 personas que toman NSAIDs morirán por un sangramiento

## Identifíquelo

### 1. BENEFICIO

El primer paso al seleccionar un medicamento para el dolor es identificar el tipo de alivio para el dolor que necesita.

#### ¿Quiere ser más activo?

Los medicamentos para el alivio del dolor pueden ayudarle a mantenerse en movimiento. Comience con poco. Utilice para el dolor leve pastillas de baja concentración y dosis. Trate la crema de piel de capsaicina (Theragen^®^, Zostrix^®^) o el acetaminofén (Tylenol®), ya que tienen menos riesgos que los otros medicamentos para alivio del dolor.

#### ¿Quiere reducir la hinchazón e inflamación?

Trate pastillas NSAID tales como naproxeno (Aleve^®^) o ibuprofeno (Advil^®^, Motrin^®^). Usted puede disminuir su riesgo de problemas utilizando la dosis más baja que pueda, por el tiempo más corto que pueda.

### 2. RIESGO

El segundo paso es conocer su riesgo de problemas, como sangramiento estomacal y problemas del corazón.

#### ¿Ha tenido alguna vez sangramiento estomacal o le han dicho que tiene un alto riesgo de sangramiento?

No utilice pastillas NSAID, incluyendo aspirina, a menos que sean recomendadas por su médico o enfermera. La mejor manera de evitar sangramiento estomacal es utilizar acetaminofén (Tylenol^®^) como su pastilla para el dolor, o use la crema de cuerpo de capsaicina (Zostrix^®^, Theragen^®^).

#### ¿Alguna vez ha tenido un ataque al corazón o le han dicho que tiene un alto riesgo de uno?

La mayoría de las personas pueden tomar acetaminofén (Tylenol^®^), aspirina, o naproxeno (Aleve^®^, Naprosyn^®^). Existe una posibilidad de problemas del corazón con otras pastillas para aliviar el dolor, por consiguiente hable con su médico o enfermera antes de probarlos.

#### ¿Toma usted aspirina de baja dosis?

La aspirina, aunque sea en dosis pequeñas, puede causar sangramiento estomacal. Si usted quiere tomar aspirina de baja dosis, considere un medicamento para alivio del dolor que no sea una pastilla NSAID, como la crema de cuerpo de capsaicina (Theragen^®^, Zostrix^®^), acetaminofén (Tylenol^®^), o glucosamina y condroitina.

Advertencia—

El combinar la aspirina con otras pastillas NSAID hace que el sangramiento sea más probable.

### 3. COSTO

El tercer paso es averiguar sobre el costo.

#### ¿Representa el costo un problema para usted?

Utilice las siguientes tablas para comparar los precios de los diferentes medicamentos. Si los medicamentos por prescripción están incluidos en su plan de seguro médico, averigüe con su plan el costo para usted.

MEDICAMENTOS PARA EL DOLOR SIN PRESCRIPCIÓN^*^

NOMBRE DEL MEDICAMENTO | NOMBRE DE LA MARCA | CONCENTRACIÓN^**^ | PRECIO por 100 PASTILLAS ó 1 TUBO^***^
NOMBRE DEL MEDICAMENTO | NOMBRE DE LA MARCA | CONCENTRACIÓN^**^ | GENÉRICO | DE MARCA
Acetaminofén | Tylenol® | 325 mg | $2 | $7
Acetaminofén | Tylenol® | 500 mg | $3 | $8
NSAIDs ORALES
Aspirina | Bayer®, Ecotrin® | 325 mg | $2 | ND
Aspirina | Bayer®, Ecotrin® | 325 mg EC | $2 | $5
Ibuprofeno | Advil®, Motrin® | 200 mg | $4 | $10
Naproxeno | Aleve® | 220 mg | $7 | $8
CREMAS TÓPICAS
Capsaicina | Theragen®, Zostrix® | Tubo de 60 gm (.025%) | $8 | $12
Capsaicina | Theragen®, Zostrix® | Tubo de 60 gm (.075%) | ND | $17
SUPLEMENTOS
Glucosamina hidroclorida más sulfato de condroitina | | 500 mg/400 mg tres veces al dia | $55 | ND

* Este cuadro incluye los medicamentos para el alivio del dolor proveniente de los estudios de investigación. Los nombres de las marcas de los medicamentos sin prescripción son sólo unos cuantos ejemplos de aquellos vendidos en el 2005.

** EC = enteric coated, en inglés; revestimiento entérico (ayuda a prevenir daño estomacal).

*** Precio promedio al por mayor proviene del Drug Topics Redbook, 2006.

ND = no disponible.

MEDICAMENTOS NSAID PARA ALIVIO DEL DOLOR POR PRESCRIPCIÓN^*^

NOMBRE DEL MEDICAMENTO | NOMBRE DE LA MARCA | DOSIS^**^ | PRECIO para PROVISIÓN DE 1 MES^***^
NOMBRE DEL MEDICAMENTO | NOMBRE DE LA MARCA | DOSIS^**^ | GENÉRICO | DE MARCA
NSAIDS TRADICIONALES
Diclofenaco | Cataflam®, Voltaren® | 75 mg dos veces al día | $70 | $160
Diclofenaco | Cataflam®, Voltaren® | 50mg tres veces al día | $85 | $175
Diclofenaco | Cataflam®, Voltaren® | 100 mg XR una vez al día | $85 | $160
Etodolaco | Lodine^®^ | 400 mg dos veces al día | $90 | $110
Etodolaco | Lodine^®^ | 400 mg tres veces al día | $130 | $170
Ibuprofeno | Motrin® | 400 mg tres veces al día | $20 | $30
Ibuprofeno | Motrin® | 800 mg tres veces al día | $35 | $45
Indometacina | Indocin® | 50 mg tres veces al día | $65 | ND
Indometacina | Indocin® | 75 mg SR dos veces al día | $130 | $140
Ketoprofeno | Oruvail® | 75 mg tres veces al día | $95 | $115
Ketoprofeno | Oruvail® | 200 mg ER una vez al día | $85 | $100
Meloxicam | Mobic® | 7.5 mg una vez al día | ND | $100
Meloxicam | Mobic® | 15 mg una vez al día | ND | $155
Nabumetona | Relafen® | 1000 mg una vez al día | $85 | $125
Nabumetona | Relafen® | 1500 mg una vez al día | $100 | $150
Naproxeno | Anaprox®, Naprelan®, Naprosyn® | 250 mg tres veces al día | $70 | $105
Naproxeno | Anaprox®, Naprelan®, Naprosyn® | 500 mg dos veces al día | $80 | $110
Naproxeno | Anaprox®, Naprelan®, Naprosyn® | 500 mg tres veces al día | $120 | $165
Piroxicam | Feldene® | 20 mg una vez al día | $75 | $115
INHIBIDOR DE COX-2
Celecoxib | Celebrex® | 100 mg dos veces al día | ND | $125
Celecoxib | Celebrex® | 200 mg dos veces al día | ND | $200
Celecoxib | Celebrex® | 400 mg dos veces al día | ND | $300
SALICILATOS
Salsalato | Disalcid®, Salflex® | 750 mg dos veces al día | $20 | $30

* Este cuadro incluye los medicamentos para el alivio del dolor proveniente de los estudios de investigación.

** XR/ER = liberación prolongada, SR= liberación sostenida.

*** Precio promedio al por mayor proviene del Drug Topics Redbook, 2006.

ND = no disponible.

## ¿Donde puedo recoger más información?

Para obtener una copia electrónica de esta guía e información sobre como seleccionar tratamientos y medicamentos, visite la siguiente página Web: www.effectivehealthcare.ahrq.gov.

Para una copia gratuita de Escogiendo medicamentos para el dolor por osteoartritis: Guía para el consumidor, llame a:

AHRQ Publications Clearinghouse (800) 358-9295

y pida la publicación número: 06(08)-EHC009-2B.

Para más información sobre la osteoartritis, visite el sitio en Internet de Medline Plus: http://www.nlm.nih.gov/medlineplus/spanish/osteoarthritis.html

## ¿Que es el fuente de esta guía?

La información en esta guía proviene de una revisión detallada de 351 reportes de investigación llamados Comparative Effectiveness and Safety of Analgesics for Osteoarthritis (2006) (Comparación Efectiva y Seguridad de los Analgésicos para la Osteoartritis).

## Related Content

Research Review

Clinician Guide

Consumer Guide