# Tratamiento para dolores de migraña grave en la sala de emergencias

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico^*^ le ha dicho que tiene dolores de cabeza a causa de migraña.
- Ha tenido que ir a la sala de emergencias^†^ (ER, por su sigla en inglés) a causa de una migraña grave.
- Usted tiene 18 años o más. La información de este resumen proviene de investigaciones en adultos.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Qué son los dolores de cabeza por migraña
- Medicamentos para tratar la migraña grave en el ER
- Qué han encontrado los investigadores respecto a la eficacia de los medicamentos
- Efectos secundarios posibles de los medicamentos
- Cosas que debe hablar con el médico del ER

Nota: Este resumen no cubre lo que han encontrado los investigadores sobre el tratamiento de la migraña en casa o las formas de prevenirla. Cubre solamente lo que han encontrado los investigadores sobre el tratamiento de las migrañas en el ER.

### ¿De dónde proviene la información?

Los investigadores revisaron estudios acerca de los medicamentos que se utilizan para tratar las migrañas en el ER. Los estudios utilizados fueron publicados hasta enero de 2012. Los investigadores recibieron financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal.

Los investigadores escribieron un informe sobre lo que encontraron y este resumen se basa en ese informe. El informe fue revisado por médicos, investigadores, otros expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/migraine-emergency.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué son los dolores de cabeza por migraña?

Los dolores de cabeza por migraña son jaquecas severas que causan un dolor intenso. Pueden empezar repentinamente y empeorar con rapidez. Por lo común, un dolor de cabeza por migraña puede durar desde 4 horas hasta 3 días si no se trata. Se piensa que la migraña se presenta de generación en generación en las familias.

Los síntomas de un dolor de cabeza por migraña pueden incluir:

- Dolor de cabeza intenso, a menudo punzante y en un lado de la cabeza
- Sensibilidad a la luz o al sonido
- Náusea y vómito
- Dificultad para realizar actividades físicas, como caminar o subir escaleras

### ¿Cuáles son otros síntomas de la migraña?

Algunas personas tienen otros síntomas antes o después de que empiece la migraña. Estos síntomas se llaman “aura” y pueden incluir:

- Entumecimiento u hormigueo en los brazos, las piernas, los dedos de las manos o en la cara
- Problemas de la vista (como pérdida temporal de la visión o ver destellos, manchas o líneas en zigzag)
- Dificultad para hablar
- Debilidad o dificultad para mover los brazos, las piernas o la cara, aunque es raro

### ¿Qué tan frecuentes son las migrañas?

- En Estados Unidos, aproximadamente 12 de cada 100 personas tienen migraña.
- La migraña es tres veces más frecuente en mujeres que en hombres.
- Cada año, una de cada siete personas que tienen migraña acuden al ER a causa de una migraña grave.
- Algunas personas pueden ir al ER por una migraña grave varias veces al año.

### ¿Qué puede causar la migraña?

Los médicos no saben exactamente qué causa las migrañas. Sin embargo, muchas cosas pueden desencadenar una migraña. Diferentes personas tienen distintos factores desencadenantes, que pueden incluir:

- Estrés o ansiedad
- Cambios hormonales (en las mujeres)
- Luces brillantes, ruidos fuertes u olores intensos
- Fumar
- Tomar bebidas alcohólicas
- Ciertos alimentos, como el chocolate, los quesos, alimentos salados o alimentos procesados
- Aditivos para alimentos, como el glutamato monosódico (MSG, por su sigla en inglés), que a veces se añade a la comida china, o el aspartame (un endulzante artificial)
- No comer lo suficiente
- No dormir lo suficiente
- Actividad física intensa
- Cambios en el clima
- Algunos medicamentos

### ¿Cómo se tratan las migrañas?

Las migrañas pueden tratarse en casa con analgésicos (medicamentos para el dolor) de venta sin receta, como el acetaminofén (Tylenol^®^), el ibuprofeno (Advil^®^ o Motrin^®^) o el naproxeno (Aleve^®^) o con medicamentos que le recete su médico. Cuando ocurre la migraña, también puede ayudar recostarse en un cuarto oscuro y tratar de dormir.

Para prevenir las migrañas, trate de evitar las cosas que sabe que pueden desencadenarlas y procure hacer ejercicio regular. Su médico puede también recetarle medicamentos que ayuden a prevenir las migrañas.

### ¿Cómo me doy cuenta de si debo ir al ER?

Si su migraña es demasiado intensa y los tratamientos mencionados no son eficaces, puede optar por ir al ER. Si decide ir al ER, asegúrese de que otra persona sea quien conduzca el auto para llevarlo.

Los síntomas de migraña se pueden confundir con los de un derrame cerebral. Debe acudir inmediatamente al hospital si:

- Tiene un dolor de cabeza extremadamente intenso (podría ser una migraña o ser algo más grave)
- Tiene problemas para hablar, para ver, moverse o mantener el equilibrio, que son nuevos o diferentes de los síntomas que solía tener con las migrañas
- Tiene rigidez de cuello o fiebre junto con el dolor de cabeza
- El dolor de cabeza se presenta repentinamente, como un “relámpago”, sobre todo si tiene usted más de 50 años

## Conozca sus opciones

### ¿Cómo se tratan las migrañas en el ER?

Para tratar el dolor de migraña intenso se utilizan diversos medicamentos en el ER, incluidos los de la lista de la página siguiente. El médico del ER puede darle también medicamentos para la náusea y tratarlo por posible deshidratación (pérdida de líquidos del cuerpo).

#### Medicamentos para alivio del dolor

Los investigadores encontraron que los medicamentos de la lista siguiente son eficaces para disminuir o detener el dolor de la migraña. Casi todos estos medicamentos se administran en forma de inyección o por medio de una sonda intravenosa (IV) colocada en el brazo. Algunos medicamentos antiinflamatorios no esteroides (NSAID, por su sigla en inglés) pueden también tomarse por vía oral.

Medicamentos | Acerca del medicamento
Neurolépticos/antieméticos; - Clorpromazina (Thorazine^®^); - Droperidol (Inapsine^®^); - Haloperidol (Haldol^®^); - Metoclopramida (Reglan^®^); - Proclorperazina (Compazine^®^) | Los neurolépticos y los antieméticos son medicamentos que cambian la forma en que ciertas sustancias químicas actúan en su cerebro. Algunos de estos medicamentos pueden también tratar la náusea y el vómito.
Sumatriptán (Alsuma^®^, Imitrex^®^, Sumavel DosePro^®^) | El sumatriptán es un medicamento para el dolor de cabeza que reduce el grosor de los vasos sanguíneos del cerebro. Nota: No deben tomar este medicamento las personas con problemas cardiacos, tales como estrechamiento o endurecimiento de los vasos sanguíneos del corazón.
NSAID; - Diclofenaco (Cataflam^®^, Voltaren^®^, Zipsor^®^); - Ketorolaco (Toradol^®^) | Los NSAID son medicamentos que alivian el dolor.
Opiáceos; - Meperidina (Demerol^®^); - Nalbufina (Nubain^®^); - Tramadol (ConZip^®^, Ryzolt^®^, Ultram^®^) | Los opiáceos son medicamentos que alivian el dolor. Sin embargo, estos medicamentos se utilizan poco para tratar la migraña, debido a sus posibles efectos secundarios y a que hay otros que son eficaces para aliviar el dolor de migraña. Nota: El uso continuo de opiáceos para aliviar el dolor puede dar lugar a su uso excesivo. Los opiáceos pueden ser adictivos.
Dihidroergotamina (D.H.E. 45^®^) | La dihidroergotamina es un medicamento para el dolor de cabeza que disminuye el grosor de los vasos sanguíneos del cerebro.

#### Medicamentos para evitar que se repita la migraña

El médico puede administrarle también un medicamento para evitar que la migraña se repita durante los siguientes uno o dos días.

Medicamentos | Acerca del medicamento | ¿Qué dicen las investigaciones sobre su eficacia?
Dexametasona (Decadron^®^) | La dexametasona es un medicamento esteroide que se usa para tratar la hinchazón y la inflamación. Puede administrarse junto con un medicamento para alivio del dolor a fin de ayudar a evitar que la migraña se repita durante los siguientes uno o dos días. Nota: Debido a sus posibles efectos secundarios, los médicos pueden recetar la dexametasona solamente a las personas con una mayor probabilidad de que la migraña se repita. | Las personas que toman dexametasona (Decadron^®^) junto con un medicamento para alivio del dolor tienen menos probabilidades de que la migraña se repita comparado con aquellas que toman solamente un medicamento para alivio del dolor.

Se necesitan más investigaciones para conocer la eficacia de otros medicamentos para evitar que la migraña se repita.

### ¿Cuáles son los efectos secundarios posibles de los medicamentos que se administran en el ER para tratar las migrañas?

Los investigadores encontraron que los efectos secundarios de estos medicamentos suelen ser menores y transitorios. Algunos de los medicamentos pueden causar sueño, de modo que no podrá usted conducir su auto enseguida. A continuación, se presenta más información sobre cada tipo de medicamento cuando se toma una sola vez en el ER para tratar una migraña grave.

- Neurolépticos / antieméticos: La inquietud en las piernas o el cuerpo es un efecto secundario frecuente. Un posible efecto secundario grave son los movimientos musculares incontrolables, como los tics y los temblores.
- Sumatriptán: El efecto secundario más frecuente es el dolor o hinchazón en el sitio de la inyección. Otros efectos secundarios pueden ser enrojecimiento de la cara y el cuello, sensación de ardor, sensación de tirantez u opresión (en el pecho, el cuello, la mandíbula u otras partes del cuerpo)^*^ y sueño.
- NSAID: No son frecuentes los efectos secundarios con estos medicamentos.
- Opiáceos: El cansancio y el sueño son efectos secundarios frecuentes.
- Dihidroergotamina: Entre los efectos secundarios más frecuentes están: dolor o hinchazón en el sitio de la inyección o donde se colocó la aguja para la IV, sueño, problemas estomacales, latido cardiaco irregular y náusea con vómito.
- Dexametasona: Los efectos secundarios no fueron frecuentes con este medicamento en los estudios de investigación. Sin embargo, entre los efectos secundarios posibles se cuentan náusea, dolor de cabeza, mareo y dificultad para dormir.

Nota: Estos medicamentos pueden tener otros efectos secundarios. Los efectos secundarios que se mencionan aquí son los más frecuentes cuando los medicamentos se toman una sola vez en el ER para tratar una migraña grave.

## Hable con el médico del ER

Tal vez quiera hablar con el médico del ER sobre:

- Su antecedente de migrañas graves y si ya ha estado antes en el ER por una migraña grave
- Todo medicamento que haya tomado para tratar una migraña grave en el pasado, qué tan eficaces fueron y todo efecto secundario que haya tenido con ellos
- Qué medicamento puede ser mejor para tratar su migraña grave
- Los beneficios y efectos secundarios posibles del medicamento

### Pregunte a su médico

- ¿Qué medicamento considera que podría ser más eficaz para mí?
- ¿Cuánto tardará en empezar a actuar?
- ¿Cuánto durará su efecto? ¿Ayudará a evitar que la migraña se repita en los próximos uno o dos días?
- ¿Hay efectos secundarios importantes a los que deba estar atento? En ese caso, ¿cuáles son?
- ¿Qué debo hacer para seguir cuidándome después de salir del ER?
- ¿Qué puedo hacer para evitar que ocurra otra migraña grave en el futuro?

Nota: Pida a su médico del ER que le anote qué medicamentos le administraron y en qué cantidades. Puede usted llevarle una copia de estos datos a su médico familiar o neurólogo, junto con una lista de todo efecto secundario que haya tenido con los medicamentos.

Tal vez le convenga también quedarse con una copia de esta información (junto con una lista de cualquier otro medicamento que esté tomando) por si tuviera que volver más adelante al ER a causa de otra migraña.

## Fuente

La información de este resumen proviene del informe Acute Migraine Treatment in Emergency Settings (Tratamiento de la migraña aguda en entornos de emergencias), de noviembre de 2012. Fue producido por el University of Alberta Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Alberta), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/migraine-emergency.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas), en el Baylor College of Medicine (Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas que tienen migraña grave.

Esta guía fue traducida de la publicación en inglés titulada Treating Severe Migraine Headaches in the Emergency Room: A Review of the Research for Adults.

* En este resumen, el término médico se refiere al profesional de la atención médica que lo atiende, como su médico, neurólogo, médico de emergencias, enfermera o asistente médico.

† La “sala de emergencias” recibe también varios otros nombres, como “departamento de emergencias”, “servicio de emergencias” o “centro de atención urgente”.

* Si tiene una sensación de opresión en el pecho, el cuello o la mandíbula, llame inmediatamente a su médico. Es probable que lo examinen por problemas cardiacos.