# Tratamientos para el colesterol alto

Guía para adultos

## Hechos resumidos

- El colesterol alto puede producir ataques cardiacos y derrames.
- Existen distintos tipos de medicamentos para tratar el colesterol alto.
- Los medicamentos más utilizados son las estatinas.
- Si su colesterol sigue estando muy alto cuando toma una estatina, hay varias opciones. Su médico o enfermera puede aumentar su dosis de estatina o agregar un medicamento para el colesterol diferente.
- Las investigaciones no nos indican todavía si el colesterol baja más cuando se combina una estatina con otro medicamento para el colesterol que cuando se toma la estatina sola.
- Las investigaciones tampoco nos indican si el uso de una estatina y otro medicamento para el colesterol aumenta la protección contra ataques al corazón o derrames que cuando se toma la estatina sola.

## ¿Qué cubre esta guía?

El mantener su colesterol en un buen nivel ayuda a reducir su riesgo de sufrir ataques al corazón y derrames. Esta guía le puede ayudar a hablar con su médico o enfermera sobre los medicamentos para tratar el colesterol alto. Se tratan los siguientes temas:

- Distintos tipos de medicamentos para el colesterol.
- Cómo funcionan los medicamentos.
- Efectos secundarios de los medicamentos para el colesterol.
- La información de esta guía proviene de una revisión, financiada por el gobierno, de la investigación sobre medicamentos para el colesterol.

## ¿Qué no cubre esta guía?

Esta guía no compara todas las formas de reducir el colesterol. No se comparan los medicamentos para el colesterol con tratamientos ya sean a base de hierbas o dietéticos (como la avena). Tampoco se comparan todas las combinaciones de medicamentos. Esta guía no cubre el tratamiento del colesterol alto en personas menores de 18 años.

## Aprenda sobre el colesterol

El colesterol es un componente fundamental de las células de nuestro cuerpo. El hígado elabora el colesterol. El colesterol llega a las células del cuerpo por la sangre. Todos necesitamos un poco de colesterol, pero nuestro cuerpo fabrica todo el que necesitamos. Algunos alimentos son una fuente agregada de colesterol.

Muchas personas tienen la cantidad correcta de colesterol. Otras tienen demasiado. A veces, el colesterol alto se presenta de generación en generación en las familias.

Existen diferentes tipos de colesterol. Los dos tipos principales suelen llamarse “malo” y “bueno.” El colesterol malo puede dañar el corazón y las arterias, pero el colesterol bueno no hace daño.

### Colesterol malo (colesterol de LDL)

Todos debemos esforzarnos por mantener lo más bajo posible el colesterol malo (LDL). Si su médico o enfermera le dice que tiene el colesterol alto, se refieren a que tiene alto el colesterol malo.

Cuando tiene demasiado colesterol malo (LDL) en la sangre, puede acumularse en las paredes de las arterias. Esta acumulación se llama placa. La placa puede estrechar las arterias y hace más difícil la circulación de la sangre. La placa puede ocasionar ataques al corazón y derrames. Mantener el colesterol malo en un nivel bajo puede ayudar a evitar estos problemas.

### Colesterol bueno (colesterol de HDL)

El colesterol bueno (HDL) ayuda a eliminar del cuerpo el exceso de colesterol. Un nivel más alto de colesterol bueno disminuye el riesgo de que ocurran enfermedades del corazón. Un nivel de 60 o más de colesterol bueno ayuda a proteger de ataques al corazón y derrames.

### Triglicéridos

Los triglicéridos son un tipo de grasa que se encuentra en la sangre. El cuerpo elabora triglicéridos. También se encuentran en los alimentos. Su cuerpo necesita este tipo de grasa, pero es mejor mantener bajos los triglicéridos. La meta suele ser menos de 150.

El tener el colesterol alto no causa síntomas. La mayoría de las personas no saben que tienen el colesterol alto a menos que se hagan un examen. El hacerse una prueba de sangre para revisar su colesterol le indicará si sus niveles son adecuados.

### Mida sus niveles de colesterol

El colesterol se mide con una prueba de sangre que se hace en el consultorio o en un laboratorio. La prueba del colesterol le indicará su nivel de colesterol total. También le indicará los niveles de su colesterol bueno (HDL) y malo (LDL), así como de sus triglicéridos.

La frecuencia con que deba hacerse esta prueba de sangre podría depender de su riesgo personal de tener ataques al corazón o derrames. Pregunte a su médico o enfermera con qué frecuencia debe medirse el colesterol.

## Establezca su meta de colesterol

Su nivel ideal de colesterol malo (LDL) depende de sus factores de riesgo de enfermedad cardiaca. Se llaman factores de riesgo a lo que aumenta la posibilidad de que ocurra un ataque cardiaco o un derrame. Si usted tiene más factores de riesgo, su médico o enfermera le recomendará una meta más baja de colesterol malo. Hable con su médico o enfermera sobre cuál debe ser su meta de colesterol.

### Factores de riesgo

Éstos son algunos factores de riesgo de las enfermedades del corazón:

- Edad.
  - En el hombre: tener 45 años o más.
  - En la mujer: tener 55 años o más.
- Antecedente familiar de enfermedad del corazón a edad temprana.
- Fumar.
- Presión arterial alta.
- Niveles bajos de colesterol bueno (HDL).

### Personas con riesgo moderado

Las personas con dos o más factores de riesgo (de los mencionados arriba) corren un riesgo moderado de tener ataques al corazón y derrames.

### Personas con riesgo alto

Las personas que padecen de enfermedades del corazón o diabetes corren un riesgo alto de tener ataques al corazón y derrames. Pertenecen a este grupo también otras personas con ciertas combinaciones de riesgos. Pregunte a su médico o enfermera si usted está en este grupo de alto riesgo.

## ¿Cómo se trata el colesterol alto?

El primer paso para controlar su colesterol es comer una dieta balanceada y ser más activo. Hasta los cambios más pequeños pueden servir de mucho. Su médico o enfermera puede recomendarle una dieta especial para bajar el colesterol.

La dieta para bajar el colesterol se basa en reglas sencillas, como:

- Comer alimentos variados, como frutas frescas, vegetales y cereales de grano entero.
- Limitar las calorías de grasas a 35 por ciento o menos del total diario de calorías ingeridas.
- Limitar los alimentos con colesterol, como la yema de huevo.
- Comer alimentos que tengan fibra, como granos enteros.

Algunas personas alcanzan su meta de colesterol comiendo una dieta balanceada y haciendo ejercicio. Sin embargo, muchas personas necesitan además medicamentos para bajar su colesterol.

## Aprenda sobre los medicamentos para el colesterol

Cada tipo de medicamento para el colesterol trabaja en forma distinta para mejorar sus niveles de colesterol. Algunos medicamentos pueden bajar sus triglicéridos. La mayoría de las personas empiezan con una estatina porque las estatinas generalmente funcionan bien para bajar el colesterol malo (LDL). Si su colesterol malo sigue estando demasiado alto, su médico o enfermera puede aumentarle la dosis de estatina o agregar un medicamento para el colesterol de otro tipo para ayudarle a alcanzar su meta. La siguiente tabla muestra los distintos tipos de medicamentos para el colesterol y cómo funcionan.

Tipos de medicamentos para el colesterol y cómo funcionan

Nombre genérico | Nombre comercial | Cómo funcionan
Estatinas
Atorvastatina | Lipitor® | Le impide al hígado elaborar colesterol.
Fluvastatina | Lescol® | Le impide al hígado elaborar colesterol.
Lovastatina | Mevacor®, Altoprev® | Le impide al hígado elaborar colesterol.
Pravastatina | Pravachol® | Le impide al hígado elaborar colesterol.
Rosuvastatina | Crestor® | Le impide al hígado elaborar colesterol.
Sinvastatina | Zocor® | Le impide al hígado elaborar colesterol.
Fijadores de ácidos biliares
Colestiramina | Questran® | Disminuye la cantidad de grasa que se absorbe de los alimentos.
Colesevelam | Welchol® | Disminuye la cantidad de grasa que se absorbe de los alimentos.
Colestipol | Colestid® | Disminuye la cantidad de grasa que se absorbe de los alimentos.
Inhibidor de la absorción del colesterol
Ezetimiba | Zetia® | Disminuye la cantidad de colesterol que se absorbe de los alimentos. Disminuye también los triglicéridos.
Fibratos
Gemfibrozil | Lopid® | Ayuda al hígado a descomponer el colesterol malo (LDL). Disminuye también los triglicéridos.
Fenofibrato | TriCor®, Lofibra®
Vitaminas y suplementos
Niacina | Niacor®, Niaspan® | Le impide al hígado eliminar el colesterol bueno (HDL). Disminuye también los triglicéridos.
Ácidos grasos omega 3 | Lovaza® | Aumenta el nivel del colesterol bueno (HDL). Disminuye también los triglicéridos.

## ¿Son dos medicamentos mejor que uno?

### Prevención de ataques al corazón y derrames

La investigación no ha aclarado si el uso de otro medicamento para el colesterol además de la estatina aumenta la protección contra ataques cardiacos o derrames. La razón es que la mayor parte de la investigación no ha incluido a suficientes personas ni ha durado lo suficiente.

### Disminución del colesterol

Las investigaciones no nos indican todavía si el colesterol baja más cuando se combina una estatina con otro medicamento para el colesterol que cuando se toma la estatina sola. Esto se debe a que no todos los estudios midieron el colesterol de la misma manera. Algunos midieron el colesterol total y otros midieron solamente el colesterol malo (LDL) o el bueno (HDL).

## Efectos secundarios de los medicamentos para el colesterol

### Efectos secundarios menores

Todos los medicamentos que cubre esta guía pueden causar efectos secundarios menores, como agruras (acedías), malestar estomacal y diarrea. Estos problemas suelen desaparecer y por lo general no son importantes. Avise a su médico o enfermera si estos síntomas son graves o no desaparecen.

### Efectos secundarios graves

#### Problemas musculares

Es raro, pero algunos medicamentos para el colesterol pueden dañar los músculos.

Si está usted tomando un medicamento para el colesterol y surgen dolores musculares, avise inmediatamente a su médico o enfermera.

#### Problemas del hígado

Es raro, pero algunos medicamentos para el colesterol pueden dañar el hígado.

Es posible que necesite hacerse una prueba de sangre para examinar su hígado, antes de que empiece a tomar estos medicamentos.

Las investigaciones no nos indican aún si la combinación de medicamentos para el colesterol ocasiona más o menos efectos secundarios que si se toma la estatina sola.

## Hable con su médico sobre el colesterol alto

### ¿Puedo controlar mi colesterol con una alimentación sana y actividad física?

Todas las personas con colesterol alto deben seguir una dieta para bajar el colesterol. También el ejercicio ayuda. Si no logra alcanzar su meta de colesterol con la dieta y el ejercicio solamente, tal vez deba empezar a tomar un medicamento para el colesterol. Colabore con su médico o enfermera para crear un plan que le funcione.

### ¿Se toman de la misma manera todos estos medicamentos?

Casi todos los medicamentos para el colesterol son pastillas. Algunos vienen en polvo para mezclarse con bebidas. Algunos se toman una vez al día. Otros deben tomarse más a menudo. Con algunas combinaciones, los medicamentos no pueden tomarse a la misma hora. Pregunte a su médico o enfermera qué tipo de horario será el más práctico para usted.

### ¿Qué puede decirse del costo?

Algunos medicamentos se venden también en forma genérica, que cuesta menos. Si su plan de seguro médico incluye recetas, pregunte cuál sería el costo para usted. Si necesita ayuda para pagar sus medicamentos para el colesterol, es posible que exista un programa de apoyo para usted. Póngase en contacto con la Partnership for Prescription Assistance (Alianza para la Asistencia con los Medicamentos Recetados, PPARx, por sus siglas en inglés). Página web: www.pparx.org/es. Teléfono: 888-477-2669.

### ¿Qué más puedo hacer para mantener sano mi corazón?

Un paso importante es bajar su colesterol. Pero también lo es controlar otros problemas de salud que puedan ponerlo en riesgo de sufrir ataques al corazón y derrames, como la diabetes y la presión arterial alta. También dejar de fumar es importante.

### Si logro bajar lo suficiente mi colesterol con el medicamento, ¿puedo dejar de tomar el medicamento?

La mayoría de las personas tiene que seguir tomando el medicamento para mantener bajo su colesterol. En general, los medicamentos para el colesterol son seguros, independientemente del tiempo que tenga que tomarlos.

## Lleve un control de sus niveles de colesterol

Use esta tabla para llevar un control de sus niveles de colesterol. Cada vez que le hagan un examen del colesterol, llene una columna de la tabla. De esa manera, usted y su médico o enfermera podrán ver cómo cambian sus niveles a medida que pasa el tiempo.

Mis niveles de colesterol

Fecha | Colesterol total | Colesterol bueno (HDL) | Colesterol malo (LDL) | Triglicéridos

## Lleve un control de sus medicamentos para el colesterol

Use esta tabla para llevar un control de los medicamentos para el colesterol que toma. Esto le ayudará a identificar los medicamentos que le funcionan mejor.

Mis medicamentos para el colesterol

Medicamentos | Dosis | ¿Cuándo empecé a tomar este medicamento? | Si ya no lo tomo, ¿por qué lo dejé?

## ¿Dónde puede obtener más información?

Visite www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Pulse en la guías para pacientes y consumidores si desea imprimir una copia y aprender sobre otras condiciones.

Si desea ejemplares impresos gratuitos de esta guía, llame al 800-358-9295. Pida a la AHRQ Publications Clearinghouse la Publicación AHRQ Número 09(10)-EHC024-B.

Para aprender más sobre el colesterol, visite http://nlm.nih.gov/medlineplus/spanish/cholesterol.html.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 102 informes de investigación. La revisión se titula Comparative Effectiveness of Lipid-Modifying Agents (Comparación de la efectividad de agentes modificadores de lípidos) (2009) y fue escrita por el Johns Hopkins Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia Johns Hopkins).

## Related Content

Research Review

Clinician Guide

Consumer Guide