# ¿Está pensando que le induzcan el parto?

Guía para la mujer embarazada

## Hechos resumidos

- Tener un parto con una inducción electiva significa que se da inicio al parto cerca de la fecha en que se completa el embarazo pero antes de que su cuerpo comience el parto espontáneamente. El parto puede iniciarse mediante el uso de medicamentos u otros medios para abrir el cuello uterino e iniciar las contracciones.
- Si hay problemas con el parto, puede que se necesite una cesárea (también llamada C-section en inglés). La cesárea puede hacerse tanto con el parto inducido como con el parto que se inicia espontáneamente.
- Si al iniciarse el parto, el cuello uterino está abierto y listo, menor es la probabilidad de que se necesite una cesárea.
- El riesgo de tener una cesárea con inducción electiva depende si usted ha tenido un bebé anteriormente.

## ¿Qué cubre esta guía?

Esta guía le puede ayudar a hablar con su médico o partera sobre el parto con inducción electiva. Le ayuda a responder las siguientes preguntas:

- ¿Qué es la inducción electiva?
- ¿Cuáles son los problemas posibles con la inducción electiva?
- ¿Qué no se sabe todavía sobre la inducción electiva?

Esta guía presenta lo que las investigaciones pueden o no pueden determinar sobre la inducción electiva. Se basa en una revisión, financiada por el gobierno, de la investigación sobre el parto con inducción electiva.

## ¿Qué no cubre esta guía?

Esta guía no trata el parto con inducción por razones médicas, tales como problemas de azúcar en la sangre o presión alta. No cubre el parto con inducción después de más de una semana de la fecha en que se completa el embarazo (due date, en inglés). Tampoco habla sobre el uso de medicamentos para mantener el parto en curso o fortalecerlo una vez que inicia espontáneamente.

## Información sobre la inducción electiva

### ¿Qué es un parto con inducción?

En un parto con inducción se usan medicamentos u otros métodos para dar inicio al parto. Con la inducción se inician las contracciones cuando éstas aún no han comenzado espontáneamente. El objetivo es que el útero se empiece a contraer y que el cuello uterino se abra.

- La oxitocina (Pitocin®) es un medicamento que se usa para dar inicio a las contracciones.
- Otras formas para inducir el parto pueden incluir el rompimiento de la fuente o el uso de un dispositivo similar a un globo que ayuda a abrir y ensanchar el cuello uterino.
- Su médico o partera puede recomendarle otros medicamentos que ayuden a ablandar y abrir el cuello uterino.

### ¿Qué es la inducción electiva?

La embarazada y su médico o partera pueden elegir dar inicio al parto cerca de la fecha en que se completa el embarazo si así lo deciden ambos. “Electivo” significa que se realiza por razones no relacionadas a algún problema con el embarazo.

### ¿Qué no es una inducción electiva?

Un parto con inducción debido a alguna razón médica, como un problema de presión alta, no es una inducción electiva.

Algunas veces, se les administra oxitocina (Pitocin®) a las mujeres que ya están en parto. Esto ayuda a que las contracciones sean más fuertes. Aunque se utilice el mismo medicamento, en este caso no es una inducción electiva.

### ¿Por qué podrían querer las mujeres inducir el parto?

- Por molestias físicas durante la parte final del embarazo.
- Por preocupación de poder llegar a tiempo al hospital.
- Por tener su propio médico o partera en el parto.
- Por tener a su esposo o pareja en el parto.
- Por conflictos de horario con el trabajo o guardería.

### ¿Por qué podrían no querer las mujeres inducir el parto?

- Por desear que el parto se inicie sin usar ningún medicamento.
- Por preocupación de que al usar medicamentos, el parto pueda ser más doloroso.
- Por preocupación de que el bebé pueda nacer prematuro (antes de tiempo) debido a que la fecha en que se completa el embarazo es incierta.
- Por no desear permanecer en el hospital más tiempo del necesario.
- Por preocupación de que pueda haber problemas que no se han estudiado.

## Cambios durante el parto

Durante el parto, el útero se endurece y luego se vuelve a relajar. A esto se le llama contracción. Las contracciones son más fuertes y más frecuentes a medida que el parto avanza. Ayudan a que el cuello uterino se abra y empujen al bebé fuera del útero.

El cuello uterino es la abertura del útero. Durante el parto, se abre (dilata). Su médico o partera medirá qué tan dilatado se encuentra su cuello uterino. La abertura se mide en centímetros. Por ejemplo, al inicio del parto, su cuello uterino puede dilatarse tres centímetros. Cuando el cuello uterino se dilata 10 centímetros, quiere decir que se ha abierto completamente. En ese momento la mujer generalmente empieza a pujar.

Posición del bebé durante el parto

Dilatación del cuello uterino durante el parto

## Problemas posibles

### Problemas para iniciar el parto

Cuando se induce el parto, se puede tardar mucho en comenzar o realmente ponerse en marcha. Puede que el cuello uterino tarde en abrirse. Si se presentaran estos problemas, existen alternativas para usted. Es apropiado preguntarle a su médico o partera si puede tomar un descanso y quizá irse a casa. Puede que el parto comience después. Una vez que la fuente se rompe, hay más probabilidad de infección. Se puede ir a casa sólo si su fuente no se ha roto y si usted y su bebé están sanos.

### Seguimiento y dolor

Cuando se induce el parto con medicamentos, la mujer generalmente necesita usar un monitor que registre el ritmo cardiaco del bebé. Esto significa que usted no se podrá levantar o moverse mucho durante el parto.

Los medicamentos para inducir el parto pueden causar que la mujer tenga contracciones más fuertes y más dolorosas en etapas más tempranas del parto que si comienza el parto sin estos medicamentos.

¿Cuándo no es seguro inducir el parto?

Generalmente, no es seguro inducir el parto antes de las 39 semanas de embarazo (una semana antes de que se complete el embarazo). Si se induce el parto mucho antes, el bebé puede nacer muy temprano o prematuro. Los bebés prematuros pueden tener problemas de respiración, alimentación o para mantener su temperatura normal. Si usted tiene algún problema de salud, como presión alta o diabetes, o su bebé tiene algún problema de salud, la inducción del parto antes de las 39 semanas puede, en ocasiones, ser lo correcto. El riesgo de que su bebé nazca prematuro contrarresta los peligros del problema de salud.

### Cesárea

La cesárea es una cirugía mayor en la que el bebé nace por el vientre de la madre. Si hay problemas durante el parto, se puede realizar una cesárea por el bienestar del bebé o la madre. También se puede realizar una cesárea, si el parto no avanza lo suficiente para que el bebé nazca de manera natural.

Hay mayor probabilidad de que una mujer necesite una cesárea si:

- Su cuello uterino no ha empezado a dilatarse cuando se induce el parto.
- Tendrá su primer bebé.
- Tiene mucho sobrepeso antes o durante el embarazo.

Las investigaciones no determinan si la probabilidad de que una mujer tenga una cesárea es diferente si ella elije la inducción en lugar de esperar a que el parto comience espontáneamente.

## ¿Qué se desconoce todavía?

La inducción electiva puede ayudarle si tiene un embarazo incómodo o quiere programar su parto. Sin embargo, las investigaciones no determinan si hay algún beneficio médico con la inducción electiva o si hay beneficios para el bebé cuando se utiliza la inducción electiva.

Las investigaciones demuestran que la inducción del parto no significa que los bebés tengan una mayor probabilidad de tener problemas respiratorios, infecciones graves, convulsiones, azúcar baja en la sangre o ictericia, la cual ocurre cuando la piel o parte blanca de los ojos del bebé se pone amarilla. Las investigaciones no han podido determinar otros problemas en los bebés recién nacidos.

Las investigaciones tampoco dan respuesta sobre el efecto que tendrá la inducción del parto en el uso de medicamentos para el dolor, el tiempo de estadía en el hospital, los problemas para amamantar y problemas del bebé durante el parto.

## Cosas que debe considerar

### ¿Tengo mayor probabilidad de tener una cesárea si me inducen el parto?

Las investigaciones no determinan si inducir el parto hace más probable que se tenga una cesárea, que si se espera a que el parto ocurra espontáneamente. Sin embargo, sus probabilidades de tener una cesárea son mayores si nunca ha tenido un parto vaginal.

### ¿Qué pasa si tuve una cesárea anteriormente?

La cesárea deja una cicatriz en el útero. Esta cicatriz hace que la inducción electiva sea más riesgosa. Si usted ya tuvo una cesárea, probablemente su médico le sugerirá otras opciones diferentes a la inducción electiva.

### ¿Volver a tener una inducción es diferente a la primera?

No existen muchas investigaciones sobre esto. Tome como base su experiencia pasada y hable con su médico o partera.

### ¿Cómo puedo aumentar mis probabilidades de tener un parto vaginal?

Si su cuello uterino está cerrado y quiere que se le induzca el parto, pregunte cómo podría aumentar sus probabilidades de tener un parto vaginal. Su médico o partera pueden recomendar un tipo especial de examen del cuello uterino que separa las membranas y en inglés se conoce como membrane sweeping. La separación de membranas puede realizarse en el consultorio. Asimismo, hay medicamentos para ablandar y abrir el cuello uterino. Estos medicamentos se administran en la vagina. Generalmente se inician cuando está en el hospital. Pregunte a su médico o partera si alguna de estas opciones sería adecuada para usted.

### Mi médico o partera recomienda que tenga una inducción electiva. ¿Tengo otra alternativa?

Sí. Siempre hay alternativas a la inducción electiva. Asegúrese de hablar con su médico o partera sobre lo que usted quiere.

## Preguntas para su médico o partera

- Estoy considerando tener una inducción electiva. ¿Usted realiza inducciones electivas?
- ¿Cuándo programaría una inducción?
- ¿Qué métodos usa para dar inicio al parto?
- Si mi inducción avanza lentamente y mi bebé está bien, ¿puedo tomar un descanso o regresar otro día para el parto?
- ¿Hay algo que podamos hacer para que mi cuerpo inicie el parto espontáneamente?
- ¿Cubrirá mi seguro una inducción electiva?

## ¿Dónde puedo obtener más información?

Visite www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Pulse en la guías para pacientes y consumidores si desea imprimir una copia y aprender sobre otras condiciones.

Si desea ejemplares impresos gratuitos de esta guía, llame al 800-358-9295. Pídale al AHRQ Publications Clearinghouse la Publicación de AHRQ Número 10-EHC004-B.

Para aprender más sobre el parto, visite http://www.nlm.nih.gov/medlineplus/spanish/childbirth.html.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 76 informes de investigación. La revisión se titula Maternal and Neonatal Outcomes of Elective Induction of Labor: A Systematic Review and Cost-Effectiveness Analysis (Resultados del parto con inducción electiva en la madre y el neonato: Revisión sistemática y análisis de la relacíon efectividad-costo) (2008) y fue escrita por el Stanford University-UCSF Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de California en San Francisco y la Universidad de Stanford).

## Related Content

Research Review

Clinician Guide

Consumer Guide