# Reduzca la posibilidad de tener un cálculo renal de calcio otra vez

Revisión de la investigación para adultos

## ¿Es esta infomación apropiada para mi?

### Si reúne todo lo siguiente, esta información es para usted

- Usted tuvo antes un cálculo renal (piedra en el riñón).
- Su médico^*^ le dijo que el cálculo renal era de calcio (el tipo más frecuente de cálculo renal). La investigación para este resumen se hizo solamente en personas con cálculos de calcio. Si no sabe usted qué tipo de cálculo tuvo, la información que ofrece el resumen puede igualmente serle útil.
- Quiere conocer opciones para reducir la posibilidad de volver a tener un cálculo de calcio.
- Tiene 18 años de edad o más. La información de este resumen resumen proviene de investigaciones en adultos.

### ¿Qué aprenderé en este resumen?

Este resumen le informará sobre:

- Cambios que puede hacer en su alimentación y/o con los medicamentos que toma y que le pueden ayudar a reducir la posibilidad de volver a tener un cálculo de calcio
- Lo que dicen las investigaciones sobre la eficacia de los cambios en la alimentación y el uso de medicamentos para reducir la posibilidad de volver a tener un cálculo de calcio
- Efectos secundarios posibles de los medicamentos
- Este resumen puede ayudarle a hablar con su médico sobre las opciones que ayudan a reducir la posibilidad de volver a tener un cálculo de calcio.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), agencia de investigación del gobierno federal, revisaron 28 estudios (ensayos comparativos aleatorizados) acerca de cambios alimentarios y medicamentos para reducir el riesgo de recurrencia de los cálculos renales, publicados entre enero de 1948 y noviembre de 2011. Casi todos los adultos en los estudios de investigación de este resumen eran hombres jóvenes o de edad mediana con cálculos de calcio. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/kidney-stones.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué son los cálculos renales?

Los cálculos renales son piedras duras que se forman dentro de los riñones. Sus riñones son órganos con forma de frijol que filtran la sangre para eliminar sustancias de desecho y producen la orina. La orina circula por las vías urinarias para salir del cuerpo. La orina sale de los riñones, pasa por los uréteres (tubos que conectan los riñones con la vejiga) y llega a la vejiga. La vejiga almacena la orina hasta que se elimina del cuerpo cuando la persona orina.

Los cálculos renales se forman al agruparse pequeños cristales minerales en la orina. Los cálculos renales pueden variar en tamaño y forma. Pueden ser tan pequeños como un grano de arena o tan grandes como una pelota de golf; aunque es raro que sean tan grandes.

Si un cálculo renal es lo suficientemente pequeño, puede desplazarse o “salir” por las vías urinarias y fuera del cuerpo, por sí solo. En cambio, si el cálculo es demasiado grande, puede quedar atorado en el riñón o el uréter. Este resumen se ocupa solamente de los cálculos de calcio (el tipo más común de cálculos renales).

La orina circula por las vías urinarias para salir del cuerpo. La orina sale de los riñones, pasa por los uréteres (tubos que conectan los riñones con la vejiga) y llega a la vejiga. La vejiga almacena la orina hasta que se elimina del cuerpo cuando la persona orina.

### ¿Cuáles son los síntomas de los cálculos renales?

Los síntomas de los cálculos renales pueden ser:

- Dolor agudo en la parte baja del abdomen (debajo del ombligo), la espalda, el costado o la ingle
- Náusea y vómito
- Fiebre y escalofríos
- Sangre en la orina
- Sensación de que pasa arena o partículas pequeñas cuando orina
- Dolor al orinar

### ¿Quién corre el riesgo de tener cálculos de calcio?

Varios factores pueden aumentar la posibilidad de que usted tenga cálculos de calcio:

- No tomar suficiente agua
- No recibir suficiente calcio de los alimentos que come
  - Tomar o comer alimentos ricos en calcio no aumenta la posibilidad de que usted presente cálculos de calcio. En realidad, una alimentación baja en calcio puede incluso aumentar el riesgo de tener cálculos de calcio.
- Comer en abundancia alimentos ricos en oxalato (por ejemplo: espinaca, ruibarbo, frutos secos o salvado de trigo)
- Consumir en abundancia alimentos o bebidas con mucha fructosa (por ejemplo: refrescos [gaseosas], frutas, ketchup [salsa de tomate] y otros condimentos, así como también muchos alimentos enlatados o envasados)
- Tener familiares que han tenido cálculos renales
- Haber tenido cálculos renales anteriormente

### ¿Qué tan frecuentes son los cálculos renales?

- De cada 100 hombres, aproximadamente 13 tendrán cálculos renales en algún momento de su vida.
- De cada 100 mujeres, aproximadamente 7 tendrán cálculos renales en algún momento de su vida.
- Cerca de 8 de cada 10 personas con cálculos renales tienen cálculos de calcio.

### ¿Cómo se tratan los cálculos renales y pueden éstos volver a formarse?

La mayoría de los cálculos renales logran desplazarse o “salir” por sí solos a través de las vías urinarias; es decir, de los riñones a los uréteres (tubos que conectan los riñones con la vejiga) y de ahí a la vejiga, desde donde salen finalmente del cuerpo. Los cálculos pueden o no sentirse cuando se desplazan. En algunas personas, expulsar los cálculos puede ser doloroso.

A veces, sin embargo, los cálculos renales no pueden expulsarse solos y se quedan atascados. En ese caso, se requiere tratamiento. El tratamiento puede consistir en medicamentos para disolver los cálculos, tratamiento con ondas de choque para romperlos en fragmentos pequeños y que puedan salir con más facilidad o cirugía para extraer los cálculos.

Después de haberse expulsado los cálculos renales —por sí solos o con tratamiento— o después de haberlos extraído, éstos pueden volver a formarse. Las personas que antes tuvieron un cálculo renal son más propensas a tener otro en el futuro. Por esa razón, su médico puede recomendar medidas para ayudar a reducir la posibilidad de tener otro cálculo.

Cuando no se toman medidas para reducir la posibilidad de volver a tener un cálculo renal, hasta 5 de cada 10 personas, con cálculos renales en el pasado, volverán a tenerlos.

## Conozca sus opciones

### ¿Cómo puedo reducir mi posibilidad de volver a tener un cálculo de calcio?

Su médico puede recomendarle hacer cambios en su alimentación y/o tomar medicamentos para ayudar a reducir su posibilidad de volver a tener un cálculo de calcio. Su médico puede mandarle exámenes de orina y sangre y preguntar sobre su historial médico, hábitos de alimentación y estilo de vida. A todas las personas no se les forman cálculos de calcio por las mismas razones. Su médico colaborará con usted para encontrar la mejor manera de ayudar a evitar que se vuelvan a formar cálculos de calcio.

### Realice cambios en su alimentación

Su médico puede recomendarle que haga cambios en su alimentación; por ejemplo:

- Tomar más agua
  - Debe tratar de tomar por lo menos ocho a diez vasos de 8 onzas de agua al día.
- Tomar menos refrescos (gaseosas) o eliminarlos
  - Si usted toma refrescos, debería evitar los que contienen sólo ácido fosfórico, sin ácido cítrico.
- Asegurarse de que está obteniendo suficiente calcio en los alimentos que consume
  - Aunque parezca extraño, el poco calcio en la alimentación puede en realidad aumentar su riesgo de volver a tener un cálculo de calcio. Su médico podrá decirle si usted está obteniendo suficiente calcio de sus alimentos.
  - El calcio de los suplementos dietéticos (por ejemplo: pastillas de calcio o en tabletas masticables) puede no ser tan eficaz para reducir su riesgo de volver a tener un cálculo de calcio, como lo es el calcio que aportan los alimentos. La mejor manera de asegurarse de obtener suficiente calcio es procurar que su alimentación incluya suficientes alimentos ricos en calcio. Ejemplos de alimentos ricos en calcio son: la leche, el queso y el yogur.
  - Hable con su médico acerca de cuáles alimentos ricos en calcio debe comer y si hay alguno que deba evitar.
- Comer alimentos con bajo contenido de sodio (sal)
  - Procure comer verduras y carnes frescas en vez de alimentos procesados. Si compra alimentos enlatados, cerciórese de que no tengan sal añadida.
  - En vez de sal, utilice otros condimentos para sazonar los alimentos. Cerciórese de que ninguna de las mezclas de condimentos que utiliza contengan sal.
- Mantenga una alimentación con bajo contenido de proteína animal
  - Limite la cantidad de carne, pescado y huevos que consume.
- Evite los alimentos ricos en oxalato (ejemplo: espinaca, ruibarbo, frutos secos y salvado de trigo)

Hable con su médico antes de hacer cambios en su alimentación. Asegúrese de informar a su médico de cualquier medicamento o vitamina que esté tomando.

### ¿Qué dicen las investigaciones sobre los cambios en la alimentación para reducir la posibilidad de volver a tener un cálculo de calcio?

Aunque se necesita hacer más estudios para corroborarlo, los investigadores encontraron que:

- Tomar más agua y evitar los refrescos reduce la posibilidad de volver a tener un cálculo de calcio.
- Una alimentación que contenga suficiente calcio, poco sodio, poca proteína animal y poco oxalato, puede reducir la posibilidad de volver a tener un cálculo de calcio.

### Medicamentos

Su médico puede recomendarle varios medicamentos para reducir la posibilidad de volver a tener un cálculo de calcio. La tabla siguiente contiene una lista de estos medicamentos y sus posibles efectos secundarios.

Medicamentos | Cómo actúa el medicamento | Posibles efectos secundarios
Diuréticos tiazídicos (“pastillas para orinar”); - Hidroclorotiazida (HydroDIURIL^®^, Microzide^®^); - Clortalidona (Hydone^®^ Tablet, Hygroton^®^, Thalitone^®^); - Indapamida (Lozol^®^) | Estos medicamentos disminuyen la cantidad de calcio en la orina. | - Dolor de estómago o cólicos estomacales; - Náusea y vómito; - Diarrea; - Cansancio; - Debilidad muscular o calambres; - Dolor de cabeza
Citratos^*^; - Citrato de potasio (Urocit-K^®^); - Citrato de sodio-potasio | Estos medicamentos ayudan a evitar la formación de cálculos de calcio. | - Dolor estomacal; - Náusea y vómito; - Diarrea
Alopurinol (Zyloprim^®^) | Este medicamento disminuye la cantidad de ácido úrico (una sustancia de desecho) en la sangre y la orina. Las cantidades altas de ácido úrico en su sangre u orina pueden causar la formación de cálculos de calcio. | - Náusea; - Diarrea; - Salpullido

* Según la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA por su sigla en inglés) de Estados Unidos, el consumo de citratos que contienen potasio puede tener efectos secundarios graves en personas cuyo organismo no puede eliminar el potasio, como es el caso de las que tienen problemas del riñón. Tome uno de estos citratos solamente si su médico lo receta.

### ¿Qué dicen las investigaciones respecto a los medicamentos para reducir la posibilidad de volver a tener un cálculo de calcio?

Los investigadores encontraron que:

- Cuando se combinan con un mayor consumo de agua, los diuréticos tiazídicos y los citratos funcionan para reducir la posibilidad de volver a tener un cálculo de calcio.
- Cuando se combina con un mayor consumo de agua, el alopurinol (Zyloprim^®^) funciona para reducir la posibilidad de volver a tener un cálculo de calcio en las personas que tienen niveles altos de ácido úrico (una sustancia de desecho) en la sangre o la orina.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varias cosas al decidir qué opción sería la mejor para ayudar a reducir la posibilidad de volver a tener un cálculo de calcio. Usted y su médico deben hablar acerca de lo siguiente:

- Sus hábitos alimenticios y los cambios que se le solicite hacer relacionados con su régimen alimenticio y su estilo de vida
- Los posibles beneficios de hacer cambios en su alimentación
- Los posibles beneficios y efectos secundarios de tomar medicamentos para reducir la posibilidad de volver a tener un cálculo renal
- Los costos de los medicamentos

### ¿Cuáles son los costos de los medicamentos para reducir la posibilidad de volver a tener un cálculo de calcio?

Los diuréticos tiazídicos, los citratos y el alopurinol están disponibles en forma genérica y no suelen ser muy costosos. Los costos para usted de estos medicamentos dependen de:

- Su seguro médico
- La dosis (cantidad) que necesite tomar

#### Pregunte a su médico

- ¿Podrían los cambios en mi alimentación ayudar a reducir la posibilidad de que vuelva a tener un cálculo de calcio? De ser así, ¿qué cambios tendré que hacer?
- ¿Podría algún medicamento ayudarme a reducir la posibilidad de volver a tener un cálculo de calcio? De ser así, ¿qué medicamento?
- ¿Por cuánto tiempo tendré que tomar el medicamento?
- ¿Hay algún efecto secundario grave que el medicamento produce y al que deba estar atento? ¿Cuándo debo llamarle sobre cualquier efecto secundario?
- ¿Los cambios en mi alimentación o el tomar un medicamento podrán afectar otros medicamentos que estoy tomando?
- ¿Cómo sabremos si son eficaces los cambios en la alimentación y/o el medicamento?
- ¿Hay algo más que pueda hacer para ayudar a reducir la posibilidad de volver a tener un cálculo de calcio?
- ¿Qué debo hacer si tengo otro cálculo de calcio?

## Fuente

La información de este resumen proviene del informe Recurrent Nephrolithiasis in Adults: Comparative Effectiveness of Preventive Medical Strategies (Nefrolitiasis recurrente en adultos: comparación de la efectividad de estrategias médicas preventivas), julio de 2012. El informe fue producido por el Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Minnesota), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/kidney-stones.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Este servicio está disponible (en español) en www.nlm.nih.gov/medlineplus/spanish/.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas que han tenido cálculos renales de calcio recurrentes.

Esta guía fue traducida de la publicación en inglés titulada Lowering the Chance of Getting Another Calcium Kidney Stone.

* En este resumen, el término “médico” se refiere al profesional de la atención médica, como puede ser su médico familiar, urólogo, enfermera o asistente médico.