# Uso de medicamentos antirreumáticos DMARD para niños con artritis

Revisión de la investigación para padres y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Un médico dijo que su hijo tiene “artritis idiopática juvenil” (AIJ) (antes llamada “artritis reumatoide juvenil” o ARJ), que incluye:
  - Artritis sistémica
  - Oligoartritis
  - Artritis psoriásica
  - Artritis relacionada con entesitis
  - Artritis indiferenciada
  - Poliartritis: factor reumatoide negativo
  - Poliartritis: factor reumatoide positivo
- El médico sugirió un tipo de medicamento llamado “medicamento antirreumático modificador de la enfermedad” (DMARD, por su sigla en inglés); se pronuncia Di-mard.

### No es apropiada si

- Su hijo tiene más de 16 años de edad.
- Su hijo tiene dolor articular, pero un médico no ha dicho que sea AIJ.
- El médico no ha sugerido un DMARD.

### ¿Qué cubre este resumen?

Este resumen describe las investigaciones sobre la eficacia y seguridad de los DMARD para tratar la AIJ. Explica lo que indican las investigaciones acerca de la forma en que los DMARD ayudan a los niños con AIJ, sus efectos secundarios y cuánto cuestan. Se escribió para ayudarle a hablar con su médico y decidir si un DMARD es lo mejor para su hijo.

### ¿De dónde proviene la información?

Esta información proviene de un informe en el que se revisaron 56 estudios de investigación acerca del uso de los DMARD en el tratamiento de la AIJ. El informe fue financiado por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés), organismo de investigación del gobierno federal de Estados Unidos, y revisado por clínicos, investigadores, expertos y público en general. El informe puede leerse en www.effectivehealthcare.ahrq.gov/dmardsjia.cfm (disponible sólo en inglés).

## Conozca la condición de su hijo

### ¿Qué es la AIJ?

La artritis idiopática juvenil (AIJ) es una enfermedad crónica persistente que causa hinchazón, dolor y rigidez en las articulaciones de los niños. Afecta con mayor frecuencia los tobillos, rodillas, caderas, codos, mandíbula y articulaciones de las muñecas, manos y pies. La AIJ ocurre antes de los 16 años de edad.

- La AIJ afecta de manera diferente a cada niño. Los síntomas varían de leves a graves y el número de articulaciones afectadas puede ser diferente en cada niño.
- La AIJ puede también causar fiebre, salpullido, hinchazón de ganglios e inflamación de los ojos. El dolor, la sensibilidad a la luz o la visión borrosa pueden ser signos de inflamación ocular, pero a menudo ésta no produce ningún síntoma.
- En casos raros, la AIJ puede también causar irritación alrededor del corazón y los pulmones.
- Algunos niños con AIJ desarrollan enfermedad destructiva de las articulaciones. La AIJ puede causar dolor e incapacidad para toda la vida.
- En algunos niños con AIJ el crecimiento puede retrasarse o ser muy lento. Asimismo, los huesos alrededor de las articulaciones pueden crecer a ritmos diferentes, de modo que los brazos o las piernas tengan largos diferentes.

#### ¿Qué tan frecuente es la AIJ?

Aunque es rara, la AIJ es la enfermedad de las articulaciones más común en la niñez. Cerca de 1 de cada 1,000 niños tiene AIJ. Afecta a niños de todas las razas.

#### ¿Qué causa la AIJ?

Normalmente, el sistema inmunológico protege al cuerpo de las enfermedades, destruyendo bacterias o virus. En los niños con AIJ, el sistema inmunológico ataca y destruye el tejido sano de las articulaciones. Los médicos no saben con seguridad a qué se debe esto.

#### ¿Qué más debo saber sobre la AIJ?

- Por lo general, la AIJ no pone en peligro la vida. Aunque no existe cura para la AIJ, hay medicamentos que pueden controlar los síntomas de la enfermedad y ayudar a prevenir la incapacidad a largo plazo.
- Los niños con AIJ pueden tener periodos sin dolor o hinchazón articular, llamados “remisión”. Aunque algunos niños logran largos periodos de remisión, en otros los síntomas regresan o empeoran, lo que se conoce como “crisis”. El objetivo del tratamiento es mantener a los niños en remisión y reducir al mínimo las crisis.
- La mayoría de los niños con AIJ pueden hacer deporte y ejercicio cuando sus síntomas no están en crisis.
- El médico de atención general o el pediatra pueden sugerirle que lo lleve a su hijo a un médico especialista que trata niños con problemas en las articulaciones. Este tipo de médico se llama “reumatólogo pediatra”.

## Conozca sus opciones

### ¿Cómo se trata la AIJ?

Antes de iniciar cualquier tratamiento, el médico hará muchas preguntas para entender los síntomas y actividades de su hijo. A veces los médicos utilizan cuestionarios para reunir esta información. Los médicos y enfermeras usan esta información para decidir qué tipo de medicamento será el mejor para su hijo y para evaluar el éxito del tratamiento.

El médico puede recomendar medicamentos que ayudan a su hijo con lo siguiente:

- Disminuir el dolor y la hinchazón cuando estos síntomas están en crisis.
- Reducir la frecuencia con que el niño tiene síntomas, con la finalidad de que todos desparezcan por periodos largos (“remisión”).
- Prevenir el daño doloroso y prolongado a las articulaciones.

La forma en que se trate la AIJ dependerá de la gravedad de los síntomas del niño y de qué tan bien responda a los varios tratamientos disponibles. La mayoría de los niños con AIJ comenzarán con uno o dos tipos de los siguientes medicamentos para tratar el dolor y la inflamación:

- Medicamentos antiinflamatorios no esteroideos (NSAID, por su sigla en inglés).
- Corticoesteroides inyectados en la articulación dolorosa o que se toman a veces vía oral (por la boca).

En algunos niños, los NSAID y los corticoesteroides serán lo único que se necesite para aliviar los síntomas de AIJ y para reducir el riesgo de problemas a largo plazo. Otros niños pueden necesitar un tercer tipo de medicamento, llamado “medicamento antirreumático modificador de la enfermedad”, o DMARD (por su sigla en inglés).

### ¿Qué son los DMARD?

Los DMARD son una familia de medicamentos que retardan o impiden que el sistema inmunológico destruya las articulaciones. Varios de estos medicamentos han sido aprobados por la Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA por su sigla en inglés) de Estados Unidos, para usarse en niños con AIJ.

Hay dos tipos de DMARD: los no biológicos y los biológicos. Los DMARD no biológicos se producen con sustancias químicas, como la mayoría de los medicamentos. Los DMARD biológicos son anticuerpos similares a los que el organismo fabrica, pero creados en laboratorios.

- El DMARD que con mayor frecuencia se le administra a los niños con AIJ es un producto no biológico llamado “metotrexato”. Muchos médicos prescriben el metotrexato como tratamiento estándar para la AIJ.
- Tanto los DMARD no biológicos como los biológicos se pueden agregar al tratamiento estándar en los niños con síntomas de AIJ más graves o cuando no se logra suficiente alivio de los síntomas. Los DMARD pueden tomarse juntos y con los NSAID o corticoesteroides.

#### ¿Cuál es la diferencia entre los DMARD no biológicos y los biológicos?

- Los DMARD no biológicos pueden administrarse en forma de pastillas o de inyecciones. Los DMARD biológicos deben administrarse por medio de un tubo intravenoso (IV) o en forma de inyección. El tratamiento intravenoso se debe administrar en una clínica o consultorio médico, pero la inyección se puede aplicar en una clínica, un consultorio o en casa.
- Como los DMARD no biológicos y biológicos funcionan de manera diferente, hay cierta preocupación en cuanto a seguridad. No existe suficiente investigación para conocer todas las posibles diferencias y su importancia.

DMARD no biológicos
Nombre genérico | Nombre comercial
Azatioprina | Azasan^®^; Imuran^®^
Ciclosporina A | Neoral^®^; Gengraf^®^
Penicilamina | Depen^®^; Cuprimine^®^
Leflunomida | Arava^®^
Metotrexato^*^ | Methotrexate LPF^®^
Sulfasalazina^*^ | Azulfidine^®^; Sulfazine^®^
DMARD biológicos
Nombre genérico | Nombre comercial
Abatacept^*^ | Orencia^®^
Adalimumab^*^ | Humira^®^
Anakinra | Kineret^®^
Etanercept^*^ | Enbrel^®^
Infliximab | Remicade^®^
Inmunoglobulina intravenosa (IVIG) | BayGam^®^; Carimune^®^ NF; Flebogamma^®^ 5% DIF; Gammagard^®^ S/D; Gammagard^®^ Liquid 10%; Gammar-P^®^; Gamunex^®^ 10%; Iveegam EN^®^; Octagam^®^ 5%; Panglobulin^®^; Polygam^®^ S/D; Privigen^®^ 10%; Vivaglobin^®^ Tocilizumab Actemra^®^

Todos los medicamentos de la lista han sido estudiados en niños con AIJ Los nombres seguidos de ^*^ han sido aprobados por la Food and Drug Administration (FDA, por su sigla en inglés) para tratar la AIJ. Esta lista de DMARD puede no incluir nuevos medicamentos que se estén estudiando o utilizando. Pregunte a su médico los nombres de otros DMARD que estén a su disposición.

#### ¿Qué dicen las investigaciones sobre los beneficios de los DMARD?

Los investigadores saben mucho más sobre el uso de DMARD en adultos que en niños. Es por eso, que no pueden afirmar con certeza qué tan bien funcionan estos medicamentos en los niños con AIJ. Los investigadores observaron que:

- Agregar el DMARD no biológico metotrexato al tratamiento funciona mejor que usar los NSAID y corticoesteroides solos para aliviar los síntomas de AIJ.
- Los DMARD biológicos pueden aliviar los síntomas de AIJ y reducir las crisis en algunos niños.

Un pequeño número de investigaciones encontraron que:

- Los niños que tomaban los DMARD mostraron cierta mejoría en su calidad de vida y capacidades, pero no existe investigación suficiente para saberlo con certeza.
- Los DMARD no biológicos pueden reducir los síntomas y mejorar la salud de los niños con AIJ, pero no existe suficiente investigación para saberlo con certeza.

No se ha realizado la investigación suficiente para saber si:

- Algún DMARD biológico o no biológico funciona mejor que otro para reducir el dolor y la hinchazón o para proteger del daño a las articulaciones.

#### ¿Qué dicen las investigaciones acerca de los efectos secundarios de los DMARD?

- La FDA advierte que algunos DMARD biológicos pueden raramente ocasionar el desarrollo de infecciones infrecuentes, como la tuberculosis (llamada “TB”) e infecciones por hongos, como la candidiasis (yeast, en inglés). Por lo general, estas infecciones se investigan en los niños antes de empezar a administrar los DMARD biológicos.
- Las infecciones graves se observaron con mayor frecuencia en los niños que tomaban metotrexato y al mismo tiempo el DMARD biológico infliximab.
- La FDA advierte que algunos DMARD biológicos, llamados “bloqueadores de TNF-alfa”, como el adalimumab (Humira^®^), el etanercept (Enbrel^®^) y el infliximab (Remicade^®^), se han vinculado con cáncer en los niños, pero es un suceso raro. El cáncer que suele ocurrir es el linfoma (cáncer de los ganglios linfáticos, que son parte del sistema inmunológico).
- No existe suficiente investigación para saber si los efectos secundarios varían entre los diferentes DMARD.

## Tome una decisión

### ¿Qué otras cosas se deben considerar al tomar una decisión?

- Los síntomas de su hijo pueden ayudarle a decidir qué tratamiento es el mejor. Al contestar las preguntas del médico, asegúrese de mencionar todos los síntomas de su hijo y todo lo que a usted le preocupa. Menciónele también al médico las actividades que a su hijo le gustaría hacer.
- Al evaluar con su médico todas las opciones de tratamiento, tal vez quiera hablar sobre los compromisos que se harán para recibir los beneficios de ciertos tratamientos conociendo que vienen acompañados con riesgos de posibles efectos secundarios. En estas entrevistas, querrá que el médico le explique el riesgo, de discapacidad o enfermedad destructiva de las articulaciones, si su hijo no recibe tratamiento suficiente o ningún tratamiento.

### ¿Cuáles son los costos de los DMARD?

El costo que tengan para usted estos medicamentos dependerá de:

- El tipo de seguro médico que tenga.
- La dosis (cantidad) de medicamento que su hijo deba tomar.
- Si el medicamento existe en la forma genérica.

De los DMARD no biológicos, el más utilizado es el metotrexato. Este medicamento existe en forma genérica y de marca comercial.

El costo del metotrexato puede variar mucho de acuerdo con el peso de su hijo. El costo promedio de mayoreo del medicamento para un niño de 65 libras es de aproximadamente $60 al mes en el caso del metotrexato genérico (tabletas), $187 al mes por la marca Rheumatrex^®^ y $76 al mes por la marca Trexall^®^.

El costo de los DMARD biológicos puede variar mucho, dependiendo del peso de su hijo y del tipo de DMARD. En el caso de un niño que pese 88 libras, el costo del suministro para un mes de un DMARD biológico está entre $750 y $2,500.

### Pregunte a su médico

- ¿Qué piensa de las investigaciones sobre los DMARD?
- Dados los síntomas de mi hijo, ¿que opción de tratamiento es la mejor?
- ¿Cuáles son los efectos secundarios a corto y largo plazo de los medicamentos?
- ¿Corre mi hijo el riesgo de desarrollar infecciones o cáncer si toma estos medicamentos?
- ¿Qué puedo esperar que le suceda a mi hijo si no se le da tratamiento?

#### Otras preguntas para su médico

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

#### Anote aquí las respuestas

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

_____________________________________________________________________

## Fuente

La información de este resumen proviene del informe Disease-Modifying Antirheumatic Drugs (DMARDs) in Children With Juvenile Idiopathic Arthritis (JIA) (Medicamentos antirreumáticos modificadores de la enfermedad [DMARD, por su sigla en inglés] en niños con artritis idiopática juvenil [AIJ]). Fue producido por el Duke University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Duke), con financiamiento de la Agency for Healthcare Research and Quality (AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/dmardsjia.cfm (disponible sólo en inglés). Otra información incluida en este resumen proviene de la página web de MedlinePlus^®^, un servicio de la Biblioteca Nacional de Medicina y los Institutos Nacionales de la Salud. Esta página puede verse en www.nlm.nih.gov/medlineplus (disponible sólo en inglés).

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas.