# Insulina premezclada para la diabetes tipo 2

Guía para adultos

## Hechos resumidos

- Cuando una persona tiene diabetes tipo 2, su cuerpo no produce la insulina suficiente o no la utiliza tan bien como debería. Muchas personas con diabetes tipo 2 necesitan inyectarse insulina.
- La insulina premezclada combina dos tipos de insulina. El primer tipo ayuda al cuerpo a controlar el azúcar en la sangre (glucosa en la sangre) durante todo el día. El segundo tipo ayuda al cuerpo a controlar el azúcar en la sangre durante las comidas.
- Existen diferentes tipos de insulina premezclada.
- Los distintos tipos de insulina premezclada son igualmente eficaces para disminuir el A1c. El A1c es una prueba de sangre que muestra su promedio de azúcar en la sangre durante los últimos 2 a 3 meses.
- La posibilidad de que el azúcar en la sangre baje demasiado es igual con los distintos tipos de insulina premezclada.

## ¿Qué cubre esta guía?

La información de esta guía proviene de una revisión, financiada por el gobierno, de las investigaciones sobre insulina premezclada. En esta guía, se comparan los beneficios, efectos secundarios y costos de un nuevo tipo de insulina premezclada, con los de otros tipos de insulina y con las pastillas para la diabetes.

¿Le ha dicho su médico o enfermera que necesita insulina para tratar su diabetes tipo 2? Hay muchos tipos de insulina y muchas formas diferentes de tomarla. Esta guía le puede ayudar a conocer más sobre ellas. También puede ayudarle a hablar con su médico o enfermera para saber si la insulina premezclada es una buena opción.

## ¿Qué no cubre esta guía?

Esta guía no cubre todas las formas posibles de tratar la diabetes tipo 2. No incluye información sobre la dieta y el ejercicio. No cubre el uso de insulina en bombas ni de inyecciones sin insulina, como las de exenatida (Byetta®) o pramlintida (Symlin®). Tampoco cubre el uso de insulina en los niños, en las mujeres embarazadas ni en personas con diabetes tipo 1.

Si su médico le recomendó usar pastillas para tratar la diabetes tipo 2, la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por sus siglas en inglés), ha publicado otra guía, en español, que puede serle útil. Se llama Pastillas para la diabetes tipo 2: Guía para adultos, y puede obtenerse en el sitio Web: effectivehealthcare.ahrq.gov/spanishinfo.cfm.

## Diabetes tipo 2 e insulina

La insulina es una hormona. La produce un órgano cercano al estómago, llamado páncreas. La insulina ayuda al cuerpo a convertir en energía el azúcar de la sangre.

En la diabetes tipo 2, el páncreas no produce suficiente insulina o el cuerpo no la utiliza como debiera. El azúcar se acumula en la sangre porque el cuerpo no puede aprovecharla sin la ayuda de la insulina. Esto causa que el azúcar en la sangre se mantenga alta. A menudo, la diabetes tipo 2 es una enfermedad que afecta familias de generación en generación.

### ¿Por qué es necesario tratar la diabetes?

Si el azúcar en la sangre se mantiene alta por mucho tiempo, aumenta la posibilidad de que la persona sufra un ataque cardiaco, embolias o derrames, y amputaciones. Puede aumentar también el riesgo de ceguera, daño a los nervios y daños en los riñones. La posibilidad de que surjan estos problemas disminuye si el azúcar en la sangre se mantiene en un nivel adecuado.

### ¿Cómo se trata la diabetes tipo 2?

El primer paso para controlar su azúcar en la sangre es comer una dieta balanceada y ser más activo. Hasta los cambios más pequeños pueden hacer una gran diferencia. La mayoría de las personas con diabetes tipo 2 también toman pastillas para ayudar a controlar el azúcar en la sangre.

Con el tiempo, muchas personas necesitan insulina para tratar la diabetes. Cerca de 3 de cada 10 personas con diabetes tipo 2 usan insulina.

## Aprenda sobre el azúcar en la sangre

### ¿Cómo se mide el azúcar en la sangre?

Hay dos pruebas comunes para medir el azúcar en la sangre. Éstas le ayudarán tanto a usted como a su médico para saber si el azúcar en la sangre está bajo control.

#### Piquete o pinchazo en el dedo

Una prueba consiste en un piquete o pinchazo en el dedo (o antebrazo) que puede hacerse en casa. Esta prueba se hace una o más veces al día. Es lo primero que puede hacer en la mañana antes de comer (en ayunas) o a otra hora del día, como después de la comida. Esta prueba indica el nivel de azúcar en la sangre presente al momento de hacerla. La cifra ideal en ayunas suele estar entre 80 y 120. Después de las comidas, el valor ideal suele estar por debajo de 180.

#### Prueba de sangre

La otra prueba es una prueba de sangre llamada A1c (A-uno-C). Ésta se realiza en el consultorio o en un laboratorio varias veces al año. El A1c muestra el valor promedio de azúcar en la sangre durante los últimos 2 a 3 meses. En general, la meta es que su A1c sea menos que 7.

Vigile que su azúcar en la sangre no baje demasiado

Todos los medicamentos para la diabetes pueden causar que el azúcar en la sangre baje demasiado. Cuando el azúcar en la sangre es muy bajo, se conoce como hipoglucemia. Esto puede causar que se sienta mareado, sudoroso, confundido, tembloroso, con hambre y débil.

Advertencia:

Si piensa que su azúcar está baja, coma o beba inmediatamente algo con azúcar. Su médico o enfermera puede sugerirle algunas cosas, como caramelo duro, jugos o tabletas de glucosa.

## Aprenda sobre la insulina

La insulina ayuda al cuerpo a convertir en energía el azúcar de la sangre. Siempre tenemos un poco de azúcar en la sangre. Eso significa que el páncreas tiene que producir pequeñas cantidades de insulina durante el día. Cuando come, su azúcar en la sangre aumenta. Eso significa que el páncreas necesita hacer más insulina durante las comidas. Cuando está más activo, el cuerpo utiliza más azúcar y necesita menos insulina.

Cuando uno tiene diabetes, el azúcar en la sangre se mantiene alta. Una forma de tratar la diabetes es con inyecciones de insulina. Toda la insulina que se usa para tratar la diabetes se hace en laboratorios.

Hay muchos tipos diferentes de insulina. El tipo que usted necesite dependerá de su grado de actividad, sus hábitos de alimentación y de cómo su cuerpo responde a la insulina. Su médico o enfermera trabajará con usted para que el tipo de insulina sea el adecuado a sus necesidades.

## Insulina con efecto para todo el día

Hay dos tipos de insulina que pueden controlar el azúcar en la sangre durante todo el día. Son la insulina de acción intermedia y la de acción prolongada. Los dos tipos producen un nivel bajo y constante de insulina todo el día. Eso significa, en general, que se aplican una o dos inyecciones al día.

Insulina con efecto para todo el día

| Nombre genérico | Nombre de la marca
| Insulina de acción intermedia
| NPH | Humulin®N
| NPH | Novolin®N
| Insulina de acción prolongada
| Insulina detemir | Levemir®
| Insulina glargina | Lantus®

## Insulina para las comidas

Con el tiempo, es posible que un solo tipo de insulina sea suficiente para controlar el azúcar en la sangre. Su médico o enfermera puede añadir insulina que se usa con las comidas. Hay dos tipos de insulina que controlan el azúcar en la sangre en las comidas. Son la insulina de acción rápida y la de acción corta. Estos tipos de insulina tienen un efecto rápido y duran un tiempo corto. Compensan el aumento del azúcar en la sangre que se produce al comer. Esto significa que tal vez deba aplicarse dos o más inyecciones al día.

Insulina para las comidas

| Nombre genérico | Nombre de la marca
| Insulina de acción corta
| Regular | Humulin®R
| Regular | Novolin®R
| Insulina de acción rápida
| Insulina aspartato | NovoLog®
| Insulina glulisina | Apidra®
| Insulina lispro | Humalog®

## Insulina premezclada para todo el día y las comidas

Algunas personas con diabetes necesitan los dos tipos de insulina. Necesitan insulina que actúe durante todo el día y la insulina para las comidas. La insulina premezclada combina los dos tipos de cobertura. Le da cobertura rápida para una comida, además de una cobertura prolongada para otros periodos del día. Si toma insulina premezclada, tal vez necesite menos inyecciones cada día.

Existen diferentes tipos de insulina premezclada.

- La insulina premezclada NPH/regular se hace combinando insulina NPH e insulina regular.
- La nueva insulina premezclada es el otro tipo de insulina premezclada. Se hace combinando insulina aspartato (NovoLog®) o insulina lispro (Humalog®) con una insulina de acción prolongada hecha especialmente para la mezcla.

Insulina con las dos coberturas (para todo el día y las comidas)

| Nombre genérico | Nombre de la marca
| Insulina premezclada NPH/regular
| NPH/regular 70/30 | Humulin® 70/30
| NPH/regular 70/30 | Novolin® 70/30
| NPH/regular 50/50 | Humulin® 50/50
| Nueva Insulina premezclada
| Insulina aspartato 70/30 | NovoLog® Mix 70/30
| Insulina lispro 75/25 | HumaLog® Mix 75/25
| Insulina lispro 50/50 | HumaLog® Mix 50/50

Los números en el nombre de la insulina premezclada indican el porcentaje de cada tipo de insulina presente en la mezcla. El primer número corresponde a la cantidad de insulina de acción prolongada. Por ejemplo, una mezcla de 70/30 indica que 70 por ciento de la mezcla es insulina de acción prolongada y 30 por ciento es insulina de cobertura rápida para una comida.

## Comparación de medicamentos

En algunos estudios de investigación se ha comparado la nueva insulina premezclada con otros medicamentos para la diabetes. Esta investigación puede ayudarles a usted y a su médico a decidir si la nueva insulina premezclada es una buena opción para usted. En los cuadros siguientes se indica cuál medicamento actúa mejor, según la investigación y al compararse uno con otro. También se indica cuál medicamento tiene menos probabilidad de causar efectos secundarios.

### Comparación entre la nueva insulina premezclada y las pastillas para la diabetes

La nueva insulina premezclada disminuye más el azúcar en la sangre que las pastillas para la diabetes. La nueva insulina premezclada tiende más a causar que el azúcar en la sangre baje. Puede también causar aumento de peso más que las pastillas para la diabetes.

### Comparación entre la nueva insulina premezclada y la insulina de acción prolongada

La nueva insulina premezclada puede disminuir más el A1c y el azúcar en la sangre después de las comidas, que la insulina de acción prolongada. Pero la insulina de acción prolongada es mejor para disminuir el azúcar en la sangre antes de comer. La nueva insulina premezclada tiende a causar que el azúcar en la sangre esté bajo. Puede también ocasionar mayor aumento de peso que la insulina de acción prolongada.

Comparación entre la nueva insulina premezclada y las pastillas para la diabetes

| Pastillas para la diabetes | Nueva insulina premezclada
Beneficios
Disminuye el A1c. | | actúa mejor
Baja el azúcar en la sangre en ayunas (antes de las comidas). | | actúa mejor
Baja el azúcar en la sangre después de las comidas. | | actúa mejor
Efectos secundarios
Hipoglucemia (azúcar en la sangre demasiado baja). | menos probabilidad
Aumento de peso. | menos probabilidad

Comparación entre la nueva insulina premezclada y la insulina de accíon prolongada

| Insulina de acción prolongada | Nueva insulina premezclada
Beneficios
Disminuye el A1c. | | actúa mejor
Baja el azúcar en la sangre en ayunas (antes de las comidas). | actúa mejor
Baja el azúcar en la sangre después de las comidas. | | actúa mejor
Efectos secundarios
Hipoglucemia (azúcar en la sangre demasiado baja). | menos probabilidad
Aumento de peso. | menos probabilidad

### Comparación entre la nueva insulina premezclada y la insulina premezclada NPH/regular

Los distintos tipos de insulina premezclada actúan casi igual. La nueva insulina premezclada es mejor para bajar el azúcar en la sangre después de las comidas.

Comparación entre la nueva insulina premezclada y la insulina premezclada NPH/regular

| Insulina premezclada NPH/regular | Nueva insulina premezclada
Beneficios
Disminuye el A1c. | actúa igual
Baja el azúcar en la sangre en ayunas (antes de las comidas). | actúa igual
Baja el azúcar en la sangre después de las comidas. | | actúa mejor
Efectos secundarios
Hipoglucemia (azúcar en sangre demasiado baja). | actúa igual
Aumento de peso. | actúa igual

## Preguntas para su médico

Todos los tipos de insulina ayudan al cuerpo a controlar el azúcar en la sangre. Hable con su médico o enfermera sobre el tipo de insulina que le funcionaría mejor a usted. Éstas son algunas de las cosas que debe preguntar.

### ¿Qué tan seguido necesito aplicarse insulina?

Algunos tipos de insulina se aplican solamente una vez al día. Otros deben aplicarse más seguido, o con las comidas. Es posible que necesite menos inyecciones si le prescriben insulina premezclada. Pregunte a su médico o enfermera con qué frecuencia deberá aplicarse la insulina.

Independientemente del tipo de insulina que use, siempre siga las instrucciones que vienen con el medicamento.

### ¿Son más fáciles de medir y de inyectar algunos tipos de insulina?

Algunas personas usan insulina que dura todo el día e insulina para las comidas. La insulina premezclada combina los dos tipos en una mezcla. Es posible que esta mezcla le facilite medir e inyectarse la insulina.

### ¿Se puede inyectar con pluma?

Cuando se usa jeringa, usted necesita llenar la jeringa de insulina. Cuando se usa pluma, no se necesita llenarla de insulina. Usted debe poner una aguja en la pluma, colocar la dosis en un marcador y aplicarse la inyección. La mayoría de los tipos de insulina están disponibles también en plumas. Esta opción puede facilitar que se inyecte y mida la insulina. Esta opción puede ser útil si tiene problemas para usar las jeringas.

### ¿Qué puede decirse del costo?

En el cuadro de la página 12, se pueden comparar los costos de distintos tipos de insulina. Si su plan de seguro médico incluye recetas, pregunte cuál sería el costo para usted. Si necesita ayuda para pagar la insulina, puede que haya un programa para ayudarle a usted. La Partnership for Prescription Assistance (Alianza para la Asistencia con los Medicamentos Recetados, PPARx, por sus siglas en inglés), puede informarle de estos programas. Sitio web: www.pparx.org/es. Teléfono: 1-888-477-2669

## Costo de la insulina

La insulina viene en frascos (viales) y plumas. Un paquete de plumas contiene más unidades de insulina que un frasco.

Nombre genérico^1^ | Nombre de la marca | Costo^2^
Nombre genérico^1^ | Nombre de la marca | Un frasco (1,000 unidades) | Plumas empaque de 5 (1,500 unidades)
Cubre todo el día
Insulina de acción intermedia
Insulina NPH | Humulin® N | $45 | $135
| Novolin® N | $45 | $135
Insulina de acción prolongada
Insulina detemir | Levemir® | $95 | $190
Insulina glargina | Lantus® | $95 | $190
Cubre el tiempo de las comidas
Insulina de acción corta
Insulina regular | Humulin® R | $45 | ND
| Novolin® R | $45 | $135
Insulina de acción rápida
Insulina aspartato | NovoLog® | $105 | $200
Insulina glulisina | Apidra® | $95 | $180
Insulina lispro | Humalog® | $105 | $200
Tiene las dos coberturas (todo el día y las comidas)
Insulina premezclada NPH/regular
70% de insulina NPH/30% de insulina regular | Humulin® 70/30 | $45 | $135
| Novolin ®70/30 | $45 | $135
50% de insulina NPH/50% de insulina regular | Humulin® 50/50 | $45 | ND
Nueva insulina premezclada
70% de insulina aspartato protamina en suspensión/30% de insulina aspartato | NovoLog® Mix 70/30 | $105 | $200
75% de insulina lispro protamina en suspensión/25% de insulina lispro | Humalog® Mix 75/25 | $105 | $200
50% de insulina lispro protamina en suspensión/50% de insulina lispro | Humalog® Mix 50/50 | $105 | $200

1 Estos medicamentos se incluyeron en los estudios de investigación.

2 El costo promedio al por mayor proviene del Red Book, 2008. No incluye el costo de agujas ni jeringas.

ND = no está disponible en plumas.

## ¿Donde puede obtener más información?

Para obtener una copia electrónica de esta guía y materiales en que se comparan tratamientos y medicamentos para otras condiciones médicas, visite este sitio web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm.

Para obtener copias gratuitas, llame a:

AHRQ Publications Clearinghouse (800) 358-9295

Pida la Publicación de AHRQ Número 08(10)-EHC017-B.

Si desea más información sobre la diabetes, visite el sitio web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/diabetes.html.

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 45 informes de investigación. La revisión se titula Comparative Effectiveness, Safety and Indications of Insulin Analogues in Premixed Formulations for Adults with Type 2 Diabetes (Comparación de la efectividad, seguridad e indicaciones de los análogos de insulina en fórmulas premezcladas para adultos con diabetes tipo 2) (2008), y fue escrita por el Johns Hopkins Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia Johns Hopkins).

## Related Content

Research Review

Clinician Guide

Consumer Guide