# Pastillas para la diabetes tipo 2

Guía para adultos

## Hechos resumidos

- Diferentes tipos de pastillas para la diabetes funcionan de formas distintas para controlar el azúcar en la sangre (glucosa en la sangre).
- Todas las pastillas para la diabetes en esta guía bajan el azúcar en la sangre.
- El combinar dos tipos diferentes de pastillas para la diabetes puede funcionar mejor para bajarle el azúcar en la sangre que un medicamento individual.
- Pero el combinar dos tipos de pastillas para la diabetes puede aumentar la probabilidad de que el azúcar en la sangre se le baje demasiado.
- La mayoría de las pastillas para la diabetes pueden causar un aumento de peso. Una clase, la metformina (Glucophage^®^), no hace que aumente de peso.
- Las pastillas para la diabetes no le subirán o bajarán la presión arterial tanto como para afectar su salud.

## ¿Qué cubre esta guía?

La diabetes tipo 2 significa que su cuerpo tiene un problema con la insulina. Esto causa que el azúcar en la sangre (blood sugar, en inglés) se suba demasiado. La insulina es una hormona, o químico, que el cuerpo produce y que se necesita para convertir la comida en energía. Cuando usted tiene diabetes tipo 2, su cuerpo puede que no produzca la suficiente insulina, o no utilice la insulina tan bien como debería. La diabetes se trata con insulina o medicamentos orales (pastillas).

Esta guía puede ayudarle a hablar con su médico o enfermera sobra las pastillas para la diabetes tipo 2. La guía cubre:

- Tipos comunes de pastillas para la diabetes.
- Qué tan bien funcionan en los adultos con diabetes tipo 2.
- Efectos secundarios.
- Precio.

La información en esta guía proviene de una revisión de investigación, auspiciada por el gobierno, sobre pastillas para la diabetes tipo 2.

## ¿Qué no está cubierto en esta guía?

Esta guía no cubre todas las formas posibles para tratar la diabetes tipo 2. No incluye información sobre dieta y ejercicio. No cubre la insulina o el usar estas pastillas conjuntamente con la insulina. No incluye pastillas para la diabetes más antiguas, como la clorpropamida (Diabinese^®^), o pastillas más nuevas, como la sitagliptina (Januvia^®^). No cubre a los niños, mujeres embarazadas, o la diabetes tipo 1.

## Tratamiento para la diabetes tipo 2

### ¿Por qué se debe tratar la diabetes?

Si el azúcar en la sangre se mantiene alto por largo tiempo, las personas pueden tener una mayor posibilidad de sufrir ataques al corazón, derrames, daños a los riñones, ceguera, y amputaciones. El mantener el azúcar en la sangre en un buen nivel puede reducir las posibilidades de tener estos problemas.

### ¿Cómo se trata la diabetes tipo 2?

El primer paso para controlar el azúcar en la sangre es comer una dieta balanceada y estar más activo. Aún cambios pequeños pueden hacer una gran diferencia. La mayoría de las personas también necesitan tomar medicamentos para ayudarles a mantener controlado el azúcar en la sangre.

## Aprenda sobre las pastillas para la diabetes

Diferentes tipos de pastillas para la diabetes funcionan de formas distintas para controlar el azúcar en la sangre. Si una pastilla no está funcionando los suficientemente bien por sí sola, su médico o enfermera puede que la combinen con un segundo tipo de pastilla. Esta tabla muestra los diferentes tipos de pastillas para la diabetes y cómo funcionan.

Tipos de pastillas para la diabetes y cómo funcionan

Nombre genérico | Nombre de la marca | Cómo funcionan
BIGUANIDAS
Metformina | Glucophage^®^ | Bloquea el hígado para que no pueda crear azúcar
SULFONILUREAS (SEGUNDA GENERACIÓN)
Glimepirida | Amaryl^®^ | Aumenta la cantidad de insulina en el cuerpo
Glipizida | Glucotrol^®^ | Aumenta la cantidad de insulina en el cuerpo
Gliburide | Diabeta^®^, Glynase PresTab^®^, Micronase^®^ | Aumenta la cantidad de insulina en el cuerpo
MEGLITINIDAS
Repaglinida | Prandin^®^ | Aumenta la cantidad de insulina en el cuerpo
Nateglinida | Starlix^®^ | Aumenta la cantidad de insulina en el cuerpo
TIAZOLIDINEDIONAS
Pioglitazona | Actos^®^ | Ayuda al cuerpo a utilizar mejor la insulina
Rosiglitazona | Avandia^®^ | Ayuda al cuerpo a utilizar mejor la insulina
INHIBIDORES DE ALFA-GLUCOSIDASA
Acarbosa | Precose^®^ | Disminuye la digestión del azúcar
Miglitol | Glyset^®^ | Disminuye la digestión del azúcar

## Aprenda sobre el azúcar en la sangre

### ¿Cómo se analiza el azúcar en la sangre?

Existen dos pruebas comunes para el azúcar en la sangre. Éstas le pueden ayudar a usted y a su médico a verificar que tan bien está su control de azúcar en la sangre.

#### Punción en el dedo (finger stick, en inglés)

Una prueba requiere la punción del dedo y puede hacerla en casa. Esta prueba se hace una o más veces al día. Puede hacerse a primera hora en la mañana antes de comer (en ayuno) o durante otras horas del día. Su médico o enfermera usarán esta información cuando usted vaya a su cita de control. Estas pruebas indican su nivel de azúcar en la sangre en ese momento específico. La meta es usualmente 100 a 120.

#### Prueba de sangre

La otra prueba es una prueba de sangre conocida como hemoglobina A1c (A-uno-C). Generalmente se conoce solamente como A1c. Esta prueba se hace en el consultorio de su médico o en un laboratorio, un par de veces al año. La prueba A1c muestra el nivel promedio de azúcar en la sangre durante los últimos 2–3 meses. Indica que tan bien se controla el azúcar en la sangre. Usualmente, la meta de su A1c es que esté por debajo de 7. Esto significa que los azúcares de sus pruebas de punción de dedo (finger stick, en inglés) han estado en un buen rango durante los últimos 2 a 3 meses.

### ¿Qué tanto pueden bajar las pastillas el azúcar en la sangre?

Todas las pastillas en esta guía bajan el azúcar en la sangre. La prueba de laboratorio para el nivel de azúcar en la sangre (hemoglobina A1c o sólo A1c) es la mejor manera de saber que tan bien funcionan las pastillas. La mayoría de las pastillas para la diabetes bajan su A1c alrededor de 1 punto. Esto significa que si usted comienza con un A1c de 8, el tomar una de estas pastillas lo puede bajar a 7.

El combinar dos o más tipos de pastillas para la diabetes puede bajar más el azúcar en la sangre que el tomar sólo un tipo. La mayoría de las combinaciones de pastillas pueden bajarla cerca de 1 punto adicional. Esto significa que si usted comienza con un A1c de 9 y la puede bajar a 8 con un tipo de pastilla, puede que logre bajarla a cerca de 7 si añade una segunda pastilla.

No existe mucha investigación sobre los medicamentos más nuevos—acarbosa (Precose^®^), miglitol (Glyset^®^), y nateglinida (Starlix^®^). Esto significa que no sabemos cómo se comparan con otras pastillas para la diabetes y en bajar el azúcar en la sangre.

## Compare las pastillas para la diabetes

Algunas de las pastillas para la diabetes han sido comparadas en estudios de investigación. Esto es lo que sabemos:

### Aumento de peso

Estas pastillas puede que le aumenten de peso:

- - glimepirida (Amaryl^®^)
- - glipizida (Glucotrol^®^)
- - gliburide (Diabeta^®^, Glynase PresTab^®^, Micronase^®^)
- - pioglitazona (Actos^®^)
- - rosiglitazona (Avandia^®^)
- - repaglinida (Prandin^®^)

El aumento de peso es de alrededor 2 a 10 libras.

La metformina (Glucophage^®^) no le hace aumentar de peso.

No sabemos de aumentos de peso con acarbosa (Precose^®^), miglitol (Glyset^®^), y nateglinida (Starlix^®^) debido a que no existe mucha investigación sobre esos medicamentos.

### Problemas estomacales

La metformina (Glucophage^®^) tiene una mayor probabilidad que otras pastillas para la diabetes de causar diarrea, calambres estomacales y gas. Dígale a su médico o enfermera si tiene alguno de estos problemas.

### Hinchazón

La pioglitazona (Actos^®^) y la rosiglitazona (Avandia^®^) tienen una mayor probabilidad de ocasionar retención de líquido que otras pastillas para la diabetes. Si a usted se le hincha la cara o las piernas, puede ser por retención de líquido. Dígale a su médico o enfermera.

### Colesterol

Existen diferentes tipos de colesterol. Generalmente se les conoce como “bueno” y “malo”. Un colesterol malo bajo y un colesterol bueno alto significan corazón y arterias más sanas. Hable con su médico o enfermera sobre las maneras de alcanzar la meta adecuada para usted.

Las pastillas para la diabetes son mayormente para bajar el azúcar en la sangre. Pero las investigaciones demuestran que unas pocas pueden afectar el colesterol.

#### Colesterol malo (LDL, en inglés)

Todas las personas deben tratar de mantener el colesterol malo (colesterol LDL) lo más bajo posible. El colesterol malo puede obstruir sus arterias. Esto hace que sea más difícil que la sangre circule. Las arterias obstruidas pueden causar ataques al corazón y derrames. Las personas con diabetes pueden tener más problemas, tales como ataques al corazón, cuando su colesterol malo está alto.

La metformina (Glucophage^®^) puede bajarle el colesterol malo alrededor de 10 puntos comparado con:

- - glimepirida (Amaryl^®^)
- - glipizida (Glucotrol^®^)
- - gliburide (Diabeta^®^, Glynase PresTab^®^, Micronase^®^)

Esto significa que si su colesterol malo es 120, la metformina puede bajarlo a 110.

La rosiglitazona (Avandia^®^) y la pioglitazona (Actos^®^) pueden subir el colesterol malo. La rosiglitazona (Avandia^®^) aumenta el colesterol malo 10 puntos más que la pioglitazona (Actos^®^).

#### Colesterol bueno (HDL, en inglés)

El colesterol bueno (colesterol HDL) ayuda a eliminar el colesterol extra del cuerpo. Cuando su colesterol bueno está alto, sus posibilidades de enfermedades del corazón son más bajas.

La mayoría de las pastillas para la diabetes no suben o bajan el colesterol bueno tanto como para afectar su salud.

## Cuídese de posibles problemas

### ¿Qué significa azúcar en la sangre bajo?

Cuando el azúcar en la sangre está demasiado bajo se conoce como hipoglucemia. Puede que le cause sentirse mareado, sudoroso, confundido, tembloroso, y débil.

- Todas las pastillas para la diabetes pueden causar que el azúcar en la sangre se baje demasiado.
- La glipizida (Glucotrol^®^), glimepirida (Amaryl^®^), gliburide (Diabeta^®^, Glynase PresTab^®^, Micronase^®^), y la repaglinida (Prandin^®^) tienen una mayor probabilidad de causar azúcares en la sangre muy bajos.
- El azúcar en la sangre bajo tiene una mayor probabilidad de ocurrir cuando usted toma dos o más tipos de pastillas para la diabetes.

ADVERTENCIA:

Si piensa que tiene el azúcar en la sangre bajo, coma o tome algo que contenga azúcar de inmediato. Su médico o enfermera pueden sugerirle algo como caramelos duros, jugo o tabletas de glucosa.

### ¿Qué es acidosis láctica?

El tomar pastillas para la diabetes puede aumentarle la posibilidad de una condición rara conocida como acidosis láctica. Esta condición ocurre con mayor probabilidad en las personas que toman pastillas para la diabetes y que también tienen problemas de los riñones y el hígado. Cada año, cerca de 1 de cada 10,000 personas que toman pastillas para la diabetes padecerán de acidosis láctica.

Señales comunes de acidosis láctica son:

- Dificultad para respirar.
- Vómito, o dolor estomacal.
- Debilidad o dolor muscular no usual.
- Escalofríos o sentirse mareado.

ADVERTENCIA:

Si usted presenta alguna de las señales de acidosis láctica debe llamar a su médico o enfermera inmediatamente.

### ¿Y qué sobre los problemas del corazón?

La falla cardíaca congestiva, o falla cardíaca, ocurre cuando el corazón no puede bombear suficiente sangre al resto del cuerpo. La pioglitazona (Actos^®^) y la rosiglitazona (Avandia^®^) pueden empeorar la falla congestiva cardíaca. Llame a su médico o enfermera si usted aumenta mucho de peso repentinamente, si se le hinchan la cara o las piernas, o le hace falta el aire. Estas pueden ser señales de falla cardíaca.

Los posibles riesgos de ataque al corazón con la rosiglitazona (Avandia^®^) han aparecido en las noticias. Las investigaciones no pueden indicarnos aún si la rosiglitazona (Avandia^®^) aumenta el riesgo de ataque al corazón en comparación con todas las otras pastillas para la diabetes en esta guía.

## Piense sobre las pastillas para la diabetes

Todas las pastillas para la diabetes bajan el azúcar en la sangre. Hable con su médico o enfermera sobre cuáles pastillas le funcionarán mejor. Éstas son algunas de las cosas que debe pensar ahora y algunas que pueden surgir después.

### ¿Importa cuándo o qué tan seguido toma usted el medicamento?

Algunos medicamentos para la diabetes se toman una vez al día. Otros deben tomarse más seguido o con comida. La dosis y precios de las pastillas para la diabetes tabla lista todas las pastillas y qué tan seguido deben tomarse. No importa cuál medicamento usted usa, asegúrese de seguir las instrucciones del frasco.

DOSIS Y PRECIOS DE LAS PASTILLAS PARA LA DIABETES

Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Precio para provisión de 1 mes^3^
Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Genérico | Marca
BIGUANIDAS
Metformina | Glucophage^®^ | 500 mg una vez al día | $20 | $30
Metformina | Glucophage^®^ | 500 mg dos veces al día | $40 | $60
Metformina | Glucophage^®^ | 850 mg dos veces al día | $70 | $95
Metformina | Glucophage^®^ | 1000 mg dos veces al día | $85 | $120
Metformina
Metformina | Glucophage XR^®^ | 1000 mg una vez al día | $45 | $60
Metformina | Glucophage XR^®^ | 2000 mg una vez al día | $90 | $115
SEGUNDA GENERACIÓN DE SULFONILUREAS
Glimepirida | Amaryl^®^ | 1 mg una vez al día | $10 | $15
Glimepirida | Amaryl^®^ | 2 mg una vez al día | $20 | $25
Glimepirida | Amaryl^®^ | 4 mg una vez al día | $35 | $45
Glimepirida | Amaryl^®^ | 8 mg una vez al día | $75 | $85
Glipizida | Glucotrol^®^ | 5 mg una vez al día | $10 | $15
Glipizida | Glucotrol^®^ | 10 mg una vez al día | $20 | $30
Glipizida | Glucotrol^®^ | 10 mg dos veces al día | $40 | $60
Glipizida | Glucotrol^®^ | 20 mg dos veces al día | $75 | $125
Glipizida
Glipizida | Glucotrol XL^®^ | 5 mg una vez al día | $10 | $15
Glipizida | Glucotrol XL^®^ | 20 mg una vez al día | $50 | $65
Gliburide | Diabeta^®^, Micronase^®^ | 2.5 mg dos veces al día | $30 | $35
Gliburide | Diabeta^®^, Micronase^®^ | 5 mg una vez al día | $25 | $30
Gliburide | Diabeta^®^, Micronase^®^ | 5 mg dos veces al día | $45 | $65
Gliburide
Gliburide | Glynase PresTab^®^ | 1.5 mg una vez al día | $10 | $20
Gliburide | Glynase PresTab^®^ | 3 mg una vez al día | $20 | $35
Gliburide | Glynase PresTab^®^ | 6 mg dos veces al día | $60 | $115
TIAZOLIDINEDIONAS
Pioglitazona | Actos^®^ | 15 mg una vez al día | ND | $115
Pioglitazona | Actos^®^ | 30 mg una vez al día | ND | $190
Pioglitazona | Actos^®^ | 45 mg una vez al día | ND | $205
Rosiglitazona | Avandia^®^ | 2 mg dos veces al día | ND | $145
Rosiglitazona | Avandia^®^ | 4 mg una vez al día | ND | $110
Rosiglitazona | Avandia^®^ | 8 mg una vez al día | ND | $200
MEGLITINIDAS (TOMAR ANTES DE LA COMIDA)
Repaglinida | Prandin^®^ | 0.5 mg tres veces al día | ND | $130
Repaglinida | Prandin^®^ | 1 mg tres veces al día | ND | $130
Repaglinida | Prandin^®^ | 4 mg tres veces al día | ND | $265
Nateglinida | Starlix^®^ | 60 mg tres veces al día | ND | $130
Nateglinida | Starlix^®^ | 120 mg tres veces al día | ND | $135
INHIBIDORES DE ALFA-GLUCOSIDASA (TOMAR CON COMIDA)
Acarbosa | Precose^®^ | 25 mg tres veces al día | ND | $80
Acarbosa | Precose^®^ | 50 mg tres veces al día | ND | $85
Acarbosa | Precose^®^ | 100 mg tres veces al día | ND | $105
Miglitol | Glyset^®^ | 25 mg tres veces al día | ND | $75
Miglitol | Glyset^®^ | 50 mg tres veces al día | ND | $85
Miglitol | Glyset^®^ | 100 mg tres veces al día | ND | $95
COMBINACIÓN DE PASTILLAS
Gliburide/metformina | Glucovance^®^ | 2.5 mg/500 mg dos veces al día | $65 | $75
Gliburide/metformina | Glucovance^®^ | 5 mg/500 mg dos veces al día | $65 | $75
Glimepirida/rosiglitazona | Avandaryl^®^ | 2 mg/4 mg una vez al día | ND | $120
Glimepirida/rosiglitazona | Avandaryl^®^ | 4 mg/4 mg una vez al día | ND | $120
Metformina/rosiglitazona | Avandamet^®^ | 500 mg/4 mg dos veces al día | ND | $220
Metformina/rosiglitazona | Avandamet^®^ | 1000 mg/2 mg dos veces al día | ND | $130
Metformina/pioglitazona | Actoplus Met^®^ | 500 mg/15 mg dos veces al día | ND | $180
Metformina/pioglitazona | Actoplus Met^®^ | 850 mg/15 mg dos veces al día | ND | $180

1 Estos medicamentos fueron incluidos en los estudios de investigación.

2 Las dosis son similares a aquellas utilizadas en los estudios de investigación.

3 El precio promedio al por mayor proviene del Drug Topics Red Book, 2007.

XR/XL = efecto prolongado.

ND = no está disponible como genérico.

### ¿Es el costo importante para usted?

Use la dosis y precios de las pastillas para la diabetes tabla para comparar los precios de los diferentes medicamentos. Algunos de los medicamentos están disponibles como genéricos y cuestan menos. Si las prescripciones son parte de su seguro de salud, verifique con su plan sobre el costo.

### ¿Está preocupado de aumentar de peso?

La metformina (Glucophage^®^) no causa aumento de peso. Usted puede que desee preguntarle a su médico o enfermera si la metformina (Glucophage^®^) es una buena opción para usted.

### ¿Está aún muy alto el azúcar en su sangre aún cuando está tomando la pastilla para la diabetes?

El combinar uno o más tipos de pastillas para la diabetes puede bajarle el azúcar más que si está tomando sólo una pastilla. Pregúntele a su médico o enfermera si el añadir otro medicamento para la diabetes le ayudará.

### ¿Le causa la metformina (Glucophage^®^) diarrea o gas?

Hable con su médico o farmacéutico. Puede que exista una solución. El combinar la metformina (Glucophage^®^) con otra pastilla para la diabetes puede ayudarle. Las personas tienen menos problemas estomacales cuando toman una dosis menor de metformina (Glucophage^®^) en combinación con otra pastilla para la diabetes.

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía e información sobre como seleccionar tratamientos y medicamentos, visite la siguiente página Web: www.effectivehealthcare.ahrq.gov

Para una copia gratuita de Pastillas para la diabetes tipo 2: Guía para adultos, llame a:

AHRQ Publications Clearinghouse, (800) 358–9295

y pida la publicación número: 07(08)-EHC010-2B

Para más información sobre la diabetes, visite el sitio en Internet de Medline Plus: www.nlm.nih.gov/medlineplus/spanish/diabetes.html

## ¿Quál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 216 reportes de investigación. La revisión se titula Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults With Type 2 Diabetes (2007) (Efectividad Comparativa y Seguridad de los Medicamentos Orales para los Adultos con Diabetes Tipo 2) y fue escrita por el Johns Hopkins Evidence-based Practice Center (el Centro de Práctica basada en Evidencia de Johns Hopkins).

## Related Content

Research Review

Clinician Guide

Consumer Guide