# Controle el dolor por una fractura de cadera

Guía para adultos y personas que ayudan a el cuidado

## ¿Es esta guía apropiada para mí o para la persona que cuido?

### Es apropiada si

- Usted o la persona a la que cuida es un adulto mayor (más de 50 años) que fue hospitalizado a causa de una fractura de cadera (rotura repentina de la cadera por un incidente, tal como una caída).

### No es apropiada si

- Usted o la persona a la que cuida entró al hospital por una causa distinta a una fractura de cadera o tiene dolor en la cadera, pero NO a causa de una fractura en este sitio.

### ¿De dónde proviene la información?

La información de esta guía proviene de una revisión de muchos estudios diferentes acerca de los tratamientos para adultos mayores que tienen dolor debido a una fractura de cadera. Un equipo de investigadores, médicos, enfermeras, farmacéuticos, fisioterapeutas y otros expertos revisó la investigación actual. Puede leer la revisión completa en www.effectivehealthcare.ahrq.gov/hippain.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la fractura de cadera?

Una fractura de cadera ocurre cuando se parte el hueso del muslo (llamado “fémur”) que está cerca de la articulación de la cadera. En los adultos mayores, la fractura de cadera puede ocurrir por una caída o por el uso diario del fémur, si está débil. El fémur es uno de los huesos más fuertes del cuerpo, pero puede debilitarse con la edad. Incluso una lesión menor puede hacer que este hueso se fracture.

Las personas que padecen de “osteoporosis”, una condición que debilita los huesos, son más propensas a fracturarse la cadera.

La fractura de cadera es una lesión grave que produce mucho dolor y que puede impedirle que camine. Las personas que tienen la cadera fracturada pueden tener un mayor riesgo de padecer de otros problemas, como neumonía, coágulos de sangre y debilidad muscular. Algunos repara pueden poner en peligro la vida. Por esa razón, cuando es posible, las fracturas de cadera se tratan con una operación que repara la cadera, con fisioterapia para a recuperar operacíon la fuerza tras la operación y medicamentos para aliviar el dolor.

### ¿Por qué es importante controlar el dolor?

Con el tiempo, el dolor ocasionado por una fractura de cadera puede causar:

- Delirio (confusión, mucho sueño, agitación; decir cosas sin sentido o ver cosas que no existen).
- Falta de sueño (dificultad para dormir).
- Depresión.

El dolor, si no se controla, puede interferir con el tratamiento de sus otras condiciones médicas. El dolor también puede hacer más lenta su fisioterapia y recuperación. Su médico, enfermera o fisioterapeuta le preguntarán sobre su dolor. Tal vez, le pidan calificar la intensidad de su dolor usando una escala, para ver si el tratamiento está ayudando. Es importante que les avise si todavía tiene dolor.

La intensidad y el tipo del dolor por una fractura de cadera pueden variar durante su tratamiento. Por ejemplo, el dolor puede ser diferente antes y después de una operación, durante la rehabilitación y al regresar a casa del hospital.

Si usted está cuidando a alguien que tiene dificultad para pensar o para decir lo que piensa (conocido como “demencia”), tal vez esa persona no pueda hablarle sobre su dolor. De cualquier manera, es importante controlar el dolor.

## Conozca sus opciones

### Tratamiento usual para el dolor por una fractura de cadera

Su médico puede darle medicamentos para tratar el dolor antes o después de la operación de reparación de la cadera. Algunos de ellos son:

Acetaminofén. Este “analgésico” (medicamento contra el dolor), diferente a la aspirina, suele utilizarse para tratar muchos tipos de dolor, como dolores en el cuerpo (malestar general) y de cabeza. Usualmente, por sí solo no tiene la potencia necesaria para aliviar el dolor por una fractura de cadera.

Analgésicos opiáceos (“opioides”). La morfina, codeína y oxicodona son nombres comunes para algunos de estos medicamentos. Los mismos se pueden administrar en pastillas, inyección o por un “tubito” en el brazo (llamado también “acceso IV o intravenoso”).

Algunos efectos secundarios comunes de los analgésicos opiáceos son:

- Náuseas, vómito y estreñimiento.
- Mucho sueño y confusión.
- Comezón o picazón.

Medicamentos antiinflamatorios no esteroideos; conocidos también por su sigla NSAID en inglés (o AINE en español). Algunos nombres comunes para estos medicamentos son ibuprofén y naproxeno. Estos medicamentos vienen en pastillas o jarabe.

Algunos efectos secundarios comunes de los NSAID son:

- Mareo.
- Náuseas.
- Diarrea.
- Exceso de gases.
- Irritación y sangrado del estómago e intestinos.

Avise a su médico si tiene alguno de estos efectos secundarios. Su médico puede darle medicamentos que le ayuden.

## Otras formas de reducir el dolor

Los investigadores han estudiado otras formas de controlar el dolor. Otros tratamientos son:

- Bloqueos nerviosos.
- Tracción.
- Acupresión.
- Terapia de relajación muscular.
- Neuroestimulación.

La investigación ha aportado más información sobre los bloqueos nerviosos que sobre los otros tratamientos mencionados. Se sabe muy poco de los beneficios y riesgos de la tracción, la acupresión, la terapia de relajación muscular y la neuroestimulación.

### Bloqueos nerviosos

#### ¿Qué es un bloqueo nervioso?

En el bloqueo nervioso, se utiliza un medicamento llamado “anestésico” para adormecer los nervios y evitar que sienta dolor por un corto período de tiempo. Los anestésicos son el mismo tipo de medicamento que usan los dentistas para adormecer los dientes y encías. El bloqueo nervioso le adormecerá una parte del cuerpo por un período corto de tiempo.

Su médico podría usar el bloqueo nervioso para tratar de aliviarle el dolor si usted no puede tomar medicamentos como los NSAID o los opiáceos. Los bloqueos nerviosos pueden utilizarse antes, durante o después de una operación.

Hay muchos tipos de bloqueos nerviosos. Se nombran según la parte del cuerpo donde el médico inyecta el anestésico. Su médico (o anestesiólogo o enfermera anestesista) puede inyectarle esos medicamentos en más de una parte del cuerpo, para obtener máximo alivio del dolor. En el caso de la fractura de cadera, las inyecciones suelen aplicarse alrededor de la cadera y en la región de la ingle.

### ¿Qué ventajas ofrece el bloqueo nervioso?

Algunas investigaciones indican que los bloqueos nerviosos usados antes, durante o después de una operación pueden aliviar el dolor a corto plazo, más que el tratamiento usual con analgésicos opiáceos o con un NSAID. Los bloqueos nerviosos pueden ayudarle a evitar el “delirio”, la confusión y la perturbación que el dolor o los analgésicos opiáceos pueden causar.

#### ¿Causa efectos secundarios el bloqueo nervioso?

Los investigadores no saben con certeza si los bloqueos nerviosos causan más o menos efectos secundarios que otros tratamientos que se usan para el dolor por fractura de cadera.

### Tracción

La tracción es un tratamiento en el que una parte del cuerpo se mantiene sujeta en una posición determinada. La tracción por lo general se utiliza antes de una operación.

Se han hecho pocos estudios acerca de la tracción. Estos estudios indican que cuando la tracción se aplica antes de una operación no ayuda a aliviar más el dolor que los analgésicos solos. Sin embargo, no es posible afirmar esto con certeza, ya que no existe suficiente investigación.

La tracción puede necesitarse por otras razones además del dolor.

No se sabe si el uso combinado de tracción y analgésicos aumenta el riesgo de tener efectos secundarios graves, comparado con el tomar sólo medicamentos.

### Acupresión, terapia de relajación muscular y neuroestimulación (TENS)

Aunque algunos estudios indican que estos métodos podrían ayudar, no se ha investigado lo suficiente para saber si estas opciones disminuyen el dolor que causa la fractura de cadera. Estas terapias pueden emplearse antes o después de una operación.

#### ¿Qué es la acupresión?

En la “acupresión”, un terapeuta experto aplica presión en ciertos puntos del cuerpo para aliviar el dolor que se siente en otras partes.

#### ¿Qué es la terapia de relajación muscular?

La “terapia de relajación muscular” utiliza rutinas de respiración y relajación para reducir la tensión muscular.

#### ¿Qué es la neuroestimulación?

La “neuroestimulación”, conocida por su sigla en inglés “TENS”, consiste en aplicar cantidades pequeñas de electricidad para estimular los nervios situados alrededor de la zona dolorosa.

#### ¿Ayudarán a aliviarme del dolor la acupresión, la terapia de relajación muscular o la TENS?

Los médicos no saben si el dolor de la fractura de cadera disminuye o se alivia más con la acupresión, la terapia de relajación o la TENS, que con medicamentos como los opiáceos y los NSAID.

#### ¿Cuáles son los riesgos de la acupresión, la terapia de relajación muscular y la TENS?

No se ha investigado lo suficiente para saber si estas opciones conllevan algún riesgo o pueden causar efectos secundarios en las personas con fractura de cadera.

## Tome una decisión

### Pregunte a su médico

1. ¿Qué opciones considera las mejores para controlar mi dolor?
2. ¿Con qué rápidez puedo esperar que se me alivie el dolor?
3. ¿Cuánto tiempo cree que necesitaré el tratamiento para el dolor?
4. ¿Le preocupan los efectos secundarios de alguna de estas opciones?

Otras preguntas para su médico:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de esta guía proviene del informe Pain Management Interventions for Hip Fracture (Intervenciones para controlar el dolor por fractura de cadera). Fue producida por el University of Alberta Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Alberta) mediante el financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atencíon Médica), visite www.effectivehealthcare.ahrq.gov/hippain.cfm (disponible sólo en inglés).

Esta guía fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas en la Facultad de Medicina de Baylor), en Houston, TX.