# Cirugía para hernia inguinal

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico^*^ le ha dicho que tiene una hernia inguinal; es decir, una hernia en la ingle. La hernia inguinal es una condición en la que una parte de su intestino, otros órganos o grasa abdominal sobresale por una abertura o un punto débil en los músculos de su ingle.
- Usted quiere saber qué dicen las investigaciones acerca de la cirugía para corregir la hernia inguinal.
- Usted tiene más de 18 años de edad. La información de este resumen proviene de investigaciones en adultos.

### No, esta información no es apropiada para usted si

- Su médico le ha dicho que tiene un tipo de hernia que no es la hernia inguinal. Si no está seguro de qué tipo de hernia tiene, pregunte a su médico.

### ¿Qué aprenderé en este resumen?

Este resumen le informa lo que dicen las investigaciones sobre los beneficios y los riesgos de la cirugía abierta y la cirugía laparoscópica para reparar una hernia inguinal. Puede ayudarle a hablar con su médico para saber si la cirugía es adecuada para usted y determinar qué tipo de cirugía sería la mejor. Este resumen no habla sobre cómo prepararse para una cirugía que repara la hernia inguinal, ni lo que puede suceder después de esta operación.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 151 estudios publicados entre enero de 1990 y noviembre de 2011 acerca de la cirugía para reparar una hernia inguinal. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/inguinal-hernia.cfm (disponible sólo en inglés).

Nota: El adulto típico en los estudios de investigación revisados para este resumen era un hombre:

- Con peso entre normal y un poco arriba de lo normal
- De alrededor de 55 años
- Con hernia inguinal en la ingle izquierda o derecha
- Que tenía su primera hernia en la ingle de ese lado
- Y que no necesitó cirugía de emergencia por hernia

Por esa razón, la información de investigación que se da en este resumen puede no aplicarse a mujeres, a hombres de otras edades o a personas que necesitan cirugía de emergencia para reparar una hernia.

## Conozca su condición

### ¿Qué es una hernia inguinal?

La hernia inguinal es una condición en la que una parte de su intestino, otros órganos o grasa abdominal sobresale por una abertura o un punto débil en los músculos de su ingle. Cualquier persona puede tener una hernia inguinal, desde bebés hasta adultos. Pero es mucho más frecuente en hombres que en mujeres.

Los síntomas de hernia inguinal pueden incluir:

- Un abultamiento en una o ambas ingles (el bulto puede aparecer o desaparecer cuando usted cambia de posición o se acuesta)
- En los hombres, el escroto (la bolsa que sostiene los testículos) puede inflamarse o agrandarse
- Una sensación de ardor o dolor en la zona del abultamiento, particularmente al levantar un objeto o hacer otro esfuerzo físico

El bulto de la hernia inguinal a veces duele y a veces no. A menudo, la aplicación de una presión suave sobre el bulto puede hacer que el intestino regrese al interior del abdomen. A veces, sin embargo, el intestino puede quedar atrapado en la ingle o el escroto y no es posible empujarlo de vuelta.

### ¿Qué pasa si mi intestino se queda atrapado?

Si parte de su intestino queda atrapado y no se puede empujar de vuelta al interior, puede afectar la capacidad de su intestino para desplazar el gas y las heces (desechos) por el cuerpo y hacia el exterior. Esto puede causarle la sensación de tener estreñimiento. Si cree que la hernia puede estar atrapada, llame a su médico.

Cuando la hernia está atrapada, se puede interrumpir el suministro de sangre a la parte saliente del intestino (condición denominada hernia “estrangulada”). Al faltarle sangre, esa parte del intestino podría morir y entonces tener que extirparse mediante cirugía de emergencia. Una hernia estrangulada requiere atención médica de emergencia.

Los síntomas de hernia estrangulada incluyen:

- El abultamiento se pone muy sensible y rojo
- Dolor que empeora repentinamente
- Fiebre
- Latido cardiaco rápido
- Náusea
- Vómito

Advertencia: La hernia estrangulada es una condición grave y puede poner en peligro la vida si no se realiza una cirugía para reparar la hernia inguinal. Si usted cree que puede tener una hernia estrangulada, debe llamar inmediatamente a su médico o acudir al hospital.

### ¿Qué causa una hernia inguinal?

Las hernias inguinales pueden ser causadas por varias cosas. Una causa posible es un punto débil en sus músculos inguinales, desde el nacimiento. Otra causa posible es la distensión por esfuerzo repetido de sus músculos inguinales. Entre las causas posibles de distensión están: levantar objetos pesados, pujar muy fuerte al ir al baño (tal vez a causa de estreñimiento), subir de peso o toser mucho.

### ¿Qué tan frecuentes son las hernias inguinales?

De cada 100 hombres, 25 tendrán una hernia inguinal alguna vez en la vida

De cada 100 mujeres, 2 tendrán hernia inguinal alguna vez en la vida

- El riesgo de tener hernia inguinal aumenta con la edad.
- La cirugía para reparar la hernia es uno de los tipos más comunes de cirugía que se realizan en Estados Unidos.

## Conozca sus opciones

### ¿Cómo se trata una hernia inguinal?

La única manera de reparar una hernia inguinal es con cirugía. Si la hernia no le duele, no se está agrandando y no está atrapada, tal vez quiera esperar para someterse a cirugía. Si decide esperar, su médico examinará su hernia para verificar que no empeore ni quede atrapada. Tanto el esperar como someterse a la cirugía conllevan riesgos y beneficios. Debe hablar sobre ambas opciones con su médico.

Si decide someterse a una cirugía para reparar su hernia inguinal, hay dos formas de hacerla: con cirugía abierta o con cirugía laparoscópica.

#### Cirugía abierta

En la cirugía abierta, el cirujano hace un corte en su ingle y devuelve el intestino, otros órganos o la grasa abdominal al interior del abdomen. Luego, el cirujano cierra con sutura el punto débil de sus músculos inguinales. Por lo general, el cirujano cubrirá el punto débil con una pequeña malla, antes de cerrarlo con sutura, para darle soporte adicional.

#### Cirugía laparoscópica

En la cirugía laparoscópica, el cirujano utiliza un instrumento llamado laparoscopio. El laparoscopio es un tubo delgado con una videocámara minúscula que el cirujano introduce en el abdomen a través de cortes pequeños, además de otros instrumentos pequeños, para hacer la cirugía. El laparoscopio permite al cirujano ver dentro del cuerpo y reparar la hernia sin tener que hacer un corte grande. Después de devolver el intestino, otros órganos o la grasa abdominal al interior del abdomen, el cirujano cubrirá el punto débil con una pequeña malla para reforzarlo.

### ¿Qué riesgos implica la cirugía para reparar la hernia inguinal?

La cirugía para reparar la hernia inguinal suele ser segura y las complicaciones son raras. Sin embargo, algunos riesgos posibles son:

- Sangrado
- Infección
- Dolor a largo plazo
- Una cicatriz
- Lesión de algún órgano (como los intestinos, la vejiga u otros)
- Lesión de los vasos sanguíneos que suministran sangre el testículo (del lado de la ingle operada)
- Lesión del conducto (del lado de la ingle operada) que lleva el semen (líquido que contiene los espermatozoides) del testículo al pene
- Riesgos de la anestesia general como neumonía o coágulos de sangre, aunque estos riesgos son raros

Nota: Después de la cirugía para reparar la hernia inguinal, es posible que la hernia vuelva a aparecer. La posibilidad de que reaparezca la hernia inguinal varía y puede depender de muchos factores, tales como si se hizo cirugía abierta o laparoscópica y de la experiencia que tenga su cirujano con ese tipo de cirugía.

### ¿Qué dicen las investigaciones sobre la cirugía para hernia inguinal?

Tanto la cirugía abierta como la laparoscópica son eficaces para reparar una hernia inguinal. En el diagrama siguiente se comparan los beneficios y los riesgos posibles de las cirugías abierta y laparoscópica.

En personas con hernia inguinal por primera vez^*^
Cirugía abierta
- Hay una menor posibilidad de que reaparezca la hernia que con la cirugía laparoscópica, pero no existe suficiente investigación para saberlo con certeza; - Puede haber menor riesgo de daño a los vasos sanguíneos profundos que con la cirugía laparoscópica, pero no existe suficiente investigación para saberlo con certeza
Cirugía laparoscópica
- Permite regresar más pronto al trabajo y a las actividades normales que con la cirugía abierta; - Existe menor riesgo de infección y de dolor a largo plazo que con la cirugía abierta; - Puede haber menor riesgo de que las heridas quirúrgicas del abdomen sangren que con la cirugía abierta, pero no existe suficiente investigación para saberlo con certeza
Los investigadores encontraron también que:
- El tipo de cirugía al que se somete la persona parece no influir con el tiempo que permanecerá en el hospital, pero no existe suficiente investigación para saberlo con certeza.; - Al parecer, las personas con una hernia inguinal no dolorosa y que se sometieron a cirugía para reparar la hernia, tuvieron una mejor calidad de vida un año después de la operación que las que no se operaron, pero no existe suficiente investigación para saberlo con certeza.
En las personas que tienen una hernia inguinal que ha vuelto a aparecer^**^
Cirugía laparoscópica
- Permite regresar más pronto a las actividades normales que con la cirugía abierta; - Existe menor riesgo de dolor a largo plazo que con la cirugía abierta

* Puede haber tenido hernia en la ingle del lado opuesto, pero es la primera vez que tiene una hernia de este lado.

** Ha reaparecido en el mismo punto una hernia inguinal de uno o ambos lados que ya antes le habían reparado.

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varios aspectos al decidir si la cirugía para reparar la hernia inguinal es adecuada para usted y, en tal caso, qué tipo de cirugía debe hacerse. Tal vez desee hablar con su médico sobre:

- Cuánto dolor tiene
- Cuánta actividad física realiza; entre más activo sea, hay más probabilidad de que su hernia se agrande o empeore si no se trata
- El riesgo de que su intestino quede atrapado o se estrangule
- Los posibles riesgos y beneficios de la cirugía
- Si la hernia no le duele, el balance entre los posibles riesgos y beneficios de la cirugía, tales como el dolor a largo plazo después de la cirugía
- Si decide operarse, qué tipo de cirugía se adapta mejor a sus preferencias: la cirugía abierta o la cirugía laparoscópica
- La experiencia de su cirujano con cada tipo de cirugía
- El tiempo que tendrá que permanecer en el hospital y ausentarse del trabajo y de otras actividades diarias después de la cirugía
- Los costos de la cirugía

### ¿Cuáles son los costos de la cirugía?

Los costos para usted de la cirugía para reparar la hernia inguinal dependen de su seguro médico y del tipo de cirugía que se realice.

### Pregunte a su médico

- ¿Necesito ahora la cirugía para reparar mi hernia inguinal o puedo esperar?
- ¿Alguna de mis otras condiciones de salud afectan mi capacidad de tener la cirugía?
- Si decido esperar, ¿hay actividades que debo evitar para prevenir que empeore mi hernia?
- Si decido esperar, ¿qué signos me pueden indicar que mi hernia está empeorando?
- Si decido operarme, ¿qué tipo de cirugía es mejor para mí, la abierta o la laparoscópica?
- ¿Usted hace los dos tipos de cirugía para hernia inguinal, la abierta y la laparoscópica? ¿Con qué tipo de cirugía tiene usted más experiencia?
- ¿Cuánto tiempo tardaré en recuperarme de la cirugía? ¿Cuándo puedo volver al trabajo y a las actividades físicas?
- ¿Cómo afectará la cirugía mi estilo de vida? ¿Qué debo evitar inmediatamente después de la cirugía?
- ¿Qué puedo hacer para ayudar a evitar que mi hernia inguinal vuelva a aparecer?

## Fuente

La información de este resumen proviene del informe Surgical Options for Inguinal Hernia: Comparative Effectiveness Review (Opciones de cirugía para hernia inguinal: Revisión de la eficacia comparada), de agosto de 2012. El informe fue producido por el ECRI Institute Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Instituto ECRI) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/inguinal-hernia.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con hernia inguinal.

Esta guía fue traducida de la publicación en inglés titulada Surgery for an Inguinal Hernia; A Review of the Research for Adults.

* En este resumen, el término “médico” se refiere al profesional de la atención médica en general, como puede ser su médico, enfermera o asistente médico.