# La prueba para detectar el virus de la hepatitis C

Por qué puede ser importante que se haga la prueba

## ¿Es esta información apropiada para mí?

### Esta información es para usted si tiene algo de lo siguiente

- Nació entre los años 1945 y 1965. Las personas nacidas en ese período tienen mayor probabilidad de que se les diagnostique hepatitis C.
- Tiene mayor riesgo de adquirir hepatitis C. Son factores de riesgo el haberse inyectado drogas (uso compartido de agujas), haber recibido una transfusión sanguínea antes de 1992 y los otros factores mencionados en la lista de la página 4.
- Es mayor de 18 años y desea saber más sobre la prueba para detectar el virus de la hepatitis C. Esta información proviene de investigaciones realizadas en adultos.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Qué es la hepatitis C y cómo puede ser dañina
- Quiénes corren el riesgo de adquirir hepatitis C
- Qué es la prueba de la hepatitis C
- Quién debe hacerse la prueba de la hepatitis C

Este resumen puede ayudarle a hablar con su médico para saber si debe hacerse la prueba de la hepatitis C.

Nota: El resumen no cubre tratamientos específicos para la hepatitis C crónica.

Si desea más información sobre los tratamientos, consulte el resumen Tratamiento de la hepatitis C crónica: Revisión de la investigación para adultos, el cual está disponible seleccionando la opción “en español” en www.effectivehealthcare.ahrq.gov/hep-c-treatment.cfm.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 162 estudios acerca de la prueba para la detección de hepatitis C publicados entre enero de 1947 y mayo de 2012. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/hepatitis-c-screening.cfm (disponible sólo en inglés).

Nota: Las investigaciones para este resumen no incluyeron a personas que recibieron un trasplante de hígado, personas con infección por VIH, personas tratadas con diálisis por insuficiencia renal ni a niños.

## Conozca la condición

### ¿Qué es la hepatitis C?

La hepatitis C es una enfermedad causada por un virus que infecta el hígado. El hígado es un órgano importante del cuerpo y tiene muchas funciones. Extrae del cuerpo sustancias químicas dañinas, ayuda a la digestión y procesa las vitaminas y nutrientes de los alimentos. El hígado también fabrica sustancias químicas que ayudan a la sangre a coagular cuando ocurre una herida. No se puede vivir sin el hígado.

En algunas personas con hepatitis C, la infección dura sólo poco tiempo y el cuerpo logra eliminar el virus. Sin embargo, la mayoría de las personas con hepatitis C desarrollan hepatitis C crónica.

La hepatitis C crónica es una enfermedad de larga duración que ocurre cuando el virus de la hepatitis C permanece en el cuerpo. La mayoría de las personas que tienen hepatitis C crónica no presentan síntomas durante muchos años, hasta que la infección empieza a dañarles el hígado.

### ¿De qué manera puede ser dañina la hepatitis C?

Si la hepatitis C no se trata, con el paso del tiempo (hasta 20 años o más en algunas personas), la infección puede dañar el hígado y hacer que ya no funcione debidamente. Puede causar cirrosis (cicatrices en el hígado que impiden que funcione correctamente y causan otros problemas), cáncer del hígado, insuficiencia hepática (del hígado) y la muerte.

- La hepatitis C es la causa primordial del cáncer del hígado.
- La hepatitis C es el motivo más frecuente de trasplantes de hígado en Estados Unidos.
- De cada 100 personas con hepatitis C crónica que no reciben tratamiento, hasta 20 personas desarrollarán cirrosis en los 20 años siguientes al inicio de la infección. Después de 20 años, el número de personas con hepatitis C crónica que desarrollan cirrosis puede aumentar mucho más. La cirrosis aumenta el riesgo de cáncer del hígado y muerte.
- La hepatitis C causa cerca de 15,000 muertes cada año en Estados Unidos.

### ¿Quién corre el riesgo de adquirir hepatitis C?

El virus de la hepatitis C se transmite por la sangre u otros líquidos corporales infectados. No existe vacuna para la hepatitis C.

Entre las personas con riesgo de adquirir hepatitis C están las que:

- Recibieron un producto sanguíneo (homoderivado), como factores de coagulación, por problemas de coagulación, antes de 1987^*^
- Recibieron una transfusión de sangre o trasplante de órganos antes de 1992^**^
- Se hicieron un tatuaje con instrumentos no esterilizados
- Se han inyectado drogas (administradas con agujas) o han aspirado drogas (inhaladas con un tubo, pajita o popote), aunque haya sido sólo una vez
- Estuvieron expuestas al virus de la hepatitis C en el trabajo; por ejemplo, un trabajador de atención médica que entra en contacto con sangre infectada
- Han estado muchos años en diálisis por insuficiencia renal
- Nacieron de una madre con hepatitis C
- Han estado en la cárcel

El virus de la hepatitis C no se contagia simplemente por estar cerca de una persona infectada, ni por abrazarla o darle la mano al saludar.

Una madre con hepatitis C puede transmitir el virus a su hijo durante el parto. Los investigadores encontraron que el riesgo es casi el mismo con la cesárea y con el parto vaginal. Encontraron también que el amamantar no conlleva un mayor riesgo de que el virus de la hepatitis C se transmita de la madre al hijo.

### ¿Qué tan común es la hepatitis C?

- En Estados Unidos, alrededor de 4 millones de personas tienen hepatitis C crónica.
- Cerca de tres de cada cuatro estadounidenses infectados por el virus de la hepatitis C nacieron entre 1945 y 1965 (los llamados baby boomers o personas que nacieron durante la era de natalidad explosiva).
- Cerca de 8 de cada 10 personas infectadas por el virus de la hepatitis C desarrollan hepatitis C crónica.

### ¿Cuáles son los síntomas de la hepatitis C?

La mayoría de las personas no notan ningún síntoma de la hepatitis C durante muchos años, hasta que el virus empieza a dañar el hígado. En otras, los síntomas aparecen de inmediato.

Cuando se presentan, los síntomas de la hepatitis C pueden incluir los de la lista siguiente. Sin embargo, algunos de estos síntomas pueden ser causados también por enfermedades comunes.

- Fiebre
- Malestar estomacal y náusea
- Diarrea
- Pérdida del apetito
- Agotamiento
- Ojos y piel amarillentos; lo que se llama “ictericia”
- Hinchazón del abdomen
- Fácil formación de moretones
- Más tiempo para dejar de sangrar

## Conozca la prueba para la hepatitis C

### ¿Cómo sé si tengo el virus de la hepatitis C?

Un simple examen de sangre puede mostrar si ha sido infectado por el virus de la hepatitis C en el pasado. Si el examen resulta positivo, su médico hará un segundo examen de sangre para ver si el virus todavía está en su sangre. Estos exámenes de sangre son muy exactos.

### ¿Por qué es importante hacerse la prueba de la hepatitis C?

Muchas personas que se infectan con el virus de la hepatitis C no saben que lo tienen. Por lo general, los síntomas no se manifiestan hasta que la infección empieza a dañar el hígado. En algunas personas, esto puede suceder hasta 20 años o más después de adquirir la infección.

La prueba del virus de la hepatitis C puede ayudar a identificar oportunamente a las personas infectadas para que reciban tratamiento antes de que su hígado se dañe. Para ayudar a proteger su hígado, las personas infectadas también pueden hacer cambios en su estilo de vida, como evitar las bebidas alcohólicas. La prueba puede también ayudar a identificar a las personas infectadas, de modo que puedan tomar medidas para no transmitir el virus a otras. La hepatitis C se transmite a través la sangre. La persona infectada puede evitar infectar a otras si no comparte ningún objeto que haya tenido contacto con su sangre.

### ¿Quién debe hacerse la prueba de la hepatitis C?

Los Centers for Disease Control and Prevention (Centros para el Control y la Prevención de Enfermedades; CDC^*^ por su sigla en inglés), y un grupo nacional^**^ de médicos, enfermeras y otros profesionales expertos en prevención revisaron los estudios de investigación sobre las pruebas de detección de hepatitis C y recomiendan lo siguiente:

- Los médicos deben ofrecer la prueba de la hepatitis C una sola vez a los adultos nacidos entre los años de 1945 a 1965.
- Deben hacerse la prueba los adultos con mayor riesgo de hepatitis C.
  - Son factores de riesgo el haberse inyectado drogas (uso compartido de agujas), haber recibido una transfusión de sangre antes de 1992 y los otros factores mencionados en la lista de la página 4.
  - Las personas que aún tienen el riesgo (como las que siguen inyectándose drogas) posiblemente tengan que hacerse la prueba de la hepatitis C más de una vez.

Si usted cree que debería hacerse la prueba de la hepatitis C, hable con su médico.

### ¿Qué hago si resulta que tengo hepatitis C?

La hepatitis C se puede curar, aunque no todos los que tienen hepatitis C necesitan tratarse de inmediato. Su médico le explicará si necesita tratamiento y cuándo. También puede hacer cambios en su estilo de vida para ayudar a proteger su hígado, tales como evitar bebidas alcohólicas.

Existen tratamientos que pueden ayudar al cuerpo a eliminar el virus con buenos resultados. Antes de decidir respecto al tratamiento, su médico puede hacer pruebas de sangre para detectar signos de daño en el hígado. Algunos médicos pueden sugerir también una biopsia del hígado. Durante la biopsia, el médico extrae un fragmento minúsculo del hígado en busca de signos de daño. Los resultados de la biopsia ayudan al médico a determinar si es necesario el tratamiento inmediato o si este puede esperar. Algunas personas esperan varios años antes de empezar el tratamiento.

Los tratamientos de la hepatitis C consisten en medicamentos (una inyección cada semana, junto con pastillas) que usted toma de 6 meses a un año. De cada 10 personas que terminan el tratamiento, hasta 7 logran eliminar de su cuerpo el virus de la hepatitis C. La tasa de éxito depende de varios factores, como el tipo específico del virus de la hepatitis C, el tipo de tratamiento utilizado y la duración del tratamiento.

Los medicamentos para tratar la hepatitis C pueden causar muchos efectos secundarios, como síntomas de tipo gripal, anemia (número bajo de glóbulos rojos), salpullido y depresión. A veces, los efectos secundarios pueden ser graves.

Actualmente están en desarrollo nuevos medicamentos para tratar la hepatitis C. Se considera que estos nuevos medicamentos, que se toman por la boca, son más eficaces y tienen menos efectos secundarios que los medicamentos actuales. Es probable que algunos de estos nuevos medicamentos sean aprobados en los próximos años por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés), de Estados Unidos.

Si desea más información sobre los tratamientos para la hepatitis C crónica, consulte el resumen de investigación Tratamiento de la hepatitis C crónica: Revisión de la investigación para adultos en www.effectivehealthcare.ahrq.gov/hep-c-treatment.cfm. Seleccione la opción “en español”. Para obtener copias impresas sin costo, llame a AHRQ Publications Clearinghouse, al 800-358-9295.

### ¿Cuánto cuesta la prueba de la hepatitis C?

Los costos para usted de la prueba de sangre de la hepatitis C dependen de su seguro médico. Algunos centros ofrecen pruebas de la hepatitis C gratuitas o de bajo costo.

## Tome una decisión

### ¿En qué cosas debo pensar?

Al decidir si debe hacerse la prueba de la hepatitis C, tal vez quiera considerar:

- Si nació entre los años 1945 y 1965
- Si tiene alguno de los factores de riesgo de la hepatitis C
- Si sigue teniendo riesgo de infectarse de hepatitis C
- Los beneficios de hacerse la prueba de la hepatitis C
- Qué significaría un resultado positivo de la prueba

### Pregunte a su médico

- ¿Dónde puedo hacerme la prueba de la hepatitis C?
- ¿Cuánto me costará la prueba?
- ¿Cuanto tiempo tardarán en darme los resultados de la prueba?
- Si mi prueba es negativa, ¿necesitaré repetirla?
- ¿Qué haremos si tengo una infección de hepatitis C?

## Fuente

La información de este resumen proviene del informe Screening for Hepatitis C Virus Infection in Adults (Prueba para detectar infección por el virus de la hepatitis C en adultos). Fue producido por el Oregon Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Oregon), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/hepatitis-c-screening.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas) en el Baylor College of Medicine (Facultad de Medicina de Baylor), en Houston, Texas. Este resumen fue revisado por adultos nacidos entre 1945 y 1965.

Esta guía fue traducida de la publicación en inglés titulada Testing for the Hepatitis C Virus: Why Testing May Be Important for You.

* Las pruebas para la detección en productos sanguíneos de donantes empezaron a mejorarse en 1987.

** La detección confiable de la hepatitis C en sangre donada comenzó en 1992.

* Si desea más información sobre las recomendaciones del CDC respecto a la prueba de la hepatitis C, visite www.cdc.gov/hepatitis/hcv/guidelinesc.htm (disponible sólo en inglés).

** Este grupo independiente es el U.S. Preventive Services Task Force (Comisión Especial de Servicios Preventivos de Estados Unidos). Si desea más información sobre la Comisión Especial y sus recomendaciones respecto a las pruebas de la hepatitis C, visite www.uspreventiveservicestaskforce.org/uspstf12/hepc/hepcfinalrs.pdf. (disponible sólo en inglés).