# Tratamiento de la hepatitis C crónica

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico^*^ le ha dicho que usted tiene hepatitis C crónica. La hepatitis C crónica es una enfermedad a largo plazo, ya que el virus de la hepatitis C permanece en el cuerpo y no desaparece.
- Usted desea conocer las opciones de tratamiento.
- Usted tiene 18 años de edad o más. Esta información proviene de investigaciones realizadas en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen describe las opciones de tratamiento para la hepatitis C crónica. Le informará de las investigaciones sobre la eficacia de los medicamentos para tratar esta enfermedad. Le informará también de las investigaciones sobre los efectos secundarios de estos medicamentos. No cubre la detección y el diagnóstico de la hepatitis C. Este resumen puede ayudarle a hablar con su médico respecto a qué tratamiento podría ser el mejor para usted.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 77 estudios publicados entre enero de 1947 y abril de 2012 acerca de la eficacia y los efectos secundarios de los tratamientos para la hepatitis C crónica. El informe resultante fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/hepctreatment.cfm (disponible sólo en inglés).

Nota: Las investigaciones usadas para este resumen no incluyeron a mujeres embarazadas, ni personas con infección por VIH, tratadas con diálisis o que recibieron un trasplante de órgano.

## Conozca su condición

### ¿Qué es la hepatitis C?

La hepatitis C es una enfermedad causada por un virus que infecta el hígado, un órgano importante del cuerpo. El hígado extrae del cuerpo las sustancias químicas dañinas, ayuda a la digestión y procesa las vitaminas y nutrientes de los alimentos. El hígado también fabrica sustancias químicas que ayudan a la sangre a coagular cuando uno se corta. Usted no puede vivir sin el hígado.

En algunas personas con hepatitis C, la infección dura sólo poco tiempo y el cuerpo logra liberarse del virus. Sin embargo, la mayoría de las personas infectadas con hepatitis C desarrollan hepatitis C crónica. Esta es una enfermedad a largo plazo que ocurre cuando el virus de la hepatitis C permanece en el cuerpo.

Si usted no recibe tratamiento, con el tiempo (20 a 30 años) la infección puede causarle daño al hígado e impedir que funcione correctamente. Puede causarle cicatrices en el hígado, cáncer del hígado, insuficiencia hepática (es decir, del hígado) y muerte.

Existen seis “genotipos” de la hepatitis C: los genotipos 1, 2, 3, 4, 5 y 6. El genotipo que usted tenga puede afectar el tratamiento que su médico sugiera y la eficacia del tratamiento.

El genotipo 1 es el más frecuente; 75 por ciento de las personas con hepatitis C tienen el genotipo 1. Sin embargo, las personas con este genotipo no responden tan bien al tratamiento como las que tienen los otros genotipos. Su médico puede hacer un examen de sangre para saber qué genotipo tiene usted.

### ¿Cuáles son los síntomas de la hepatitis C?

La mayoría de las personas no notan ningún síntoma de la hepatitis C hasta que el virus ha empezado a dañarles el hígado. En otras personas, los síntomas aparecen rápidamente.

Los síntomas de la hepatitis C pueden incluir:

- Cansancio
- Fiebre
- Pérdida del apetito
- Malestar estomacal
- Náusea y vómito
- Dolor en las articulaciones

Los síntomas de la hepatitis C avanzada pueden incluir:

- Ojos y piel amarillentos; lo que se llama “ictericia”
- Orina de color oscuro
- Heces de color claro
- Formación fácil de moretones
- Demorarse para dejar de sangrar

### ¿Qué tan común es la hepatitis C?

- En el mundo, cerca de 180 millones de personas tienen hepatitis C crónica.
- En Estados Unidos, tienen hepatitis C crónica alrededor de 4 millones de personas.
- Dos tercios de los estadounidenses infectados por el virus de la hepatitis C nacieron entre 1945 y 1964 (conocidos como baby boomers, en inglés).
- Entre 70 y 85 por ciento de las personas infectadas por el virus de la hepatitis C desarrollan hepatitis C crónica.^*^
- La hepatitis C causa cerca de 15,000 muertes cada año en Estados Unidos.
- La hepatitis C es la razón más común por la que se realizan trasplantes de hígado en Estados Unidos.

### ¿Cómo se adquiere la hepatitis C?

La hepatitis C se transmite por la sangre. Puede adquirir el virus cualquier persona que entre en contacto con sangre infectada.

Entre las personas con riesgo de adquirir hepatitis C están las que:

- Recibieron una transfusión de sangre o trasplante de órganos antes de 1992
- Recibieron un producto sanguíneo para tratar problemas de coagulación antes de 1987
- Se hicieron un tatuaje o perforación con instrumentos no estériles
- Compartieron agujas de inyección con una persona infectada, aunque fuera sólo una vez
- Han estado expuestas al virus de la hepatitis C en el trabajo (como en el caso de un trabajador de atención médica que entra en contacto con sangre infectada)
- Han pasado muchos años en diálisis por insuficiencia hepática (del hígado)
- Están infectadas con el VIH
- Utilizaron el cepillo de dientes o la maquinilla de afeitar (rastrillo) de una persona infectada, aunque el riesgo es bajo
- Tuvieron relaciones sexuales con una persona infectada, aunque el riesgo es bajo

El virus de la hepatitis C no puede contagiarse simplemente por estar cerca de una persona infectada, ni por darle la mano al saludar o al abrazarla.

## Conozca sus opciones

### ¿Cómo se trata la hepatitis C crónica?

Dependiendo del grado de daño a su hígado, su historial médico y sus preferencias, usted y su médico pueden decidirse por uno de los planes de tratamiento siguientes:

- Tratamiento inmediato. Si su hígado está muy dañado, su médico puede sugerirle que reciba tratamiento inmediato.
- Espera y seguimiento. Si su hígado no está muy dañado y usted no necesita tratamiento inmediato, su médico puede sugerirle que espere. Algunas personas esperan varios años antes de empezar el tratamiento. Si usted decide esperar, es probable que su médico desee examinar el hígado regularmente para saber si necesitará tratamiento y cuándo lo necesitará.

Antes de decidir cómo tratar su infección de hepatitis C crónica, es posible que algunos médicos sugieran hacer primero una biopsia del hígado. Durante la biopsia del hígado, el médico extrae un fragmento minúsculo del hígado para buscar signos de daño o enfermedad. Los resultados de la biopsia ayudan al médico a definir si ya es necesario el tratamiento o si este puede esperar.

### ¿Con qué medicamentos se trata la hepatitis C crónica?

La hepatitis C crónica se trata con una combinación de medicamentos. Algunos ayudan al sistema inmunológico a combatir el virus, mientras que otros medicamentos combaten el virus directamente.

Medicamentos para tratar la hepatitis C crónica

Nombre del medicamento | Nombre comercial | ¿Existe en genérico? | Cómo se administra
Interferones
Peginterferón alfa-2a | Pegasys^®^ | No | Inyección semanal
Peginterferón alfa-2b | Pegintron^®^ | No | Inyección semanal
Medicamento antiviral análogo de los nucleósidos
Ribavirina | Copegus^®^, Rebetol^®^, Ribasphere^®^ | Sí | Pastilla
Medicamentos antivirales inhibidores de la proteasa
Boceprevir | Victrelis^®^ | No | Pastilla
Telaprevir | Incivek^®^ | No | Pastilla

Existen actualmente dos tratamientos para tratar a las personas con hepatitis C crónica:

- Tratamiento doble: Un interferón + ribavirina

o bien

- Tratamiento triple: Un interferón + ribavirina + boceprevir o telaprevir

Pueden tomar el tratamiento doble las personas con cualquiera de los seis genotipos de la hepatitis C. El tratamiento triple está aprobado por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos solamente para las personas con el genotipo 1.

El tratamiento doble se convirtió en el método estándar para tratar la hepatitis C crónica al principio de la década de 2000. La FDA aprobó el boceprevir (Victrelis^®^) y el telaprevir (Incivek^®^) para el tratamiento triple en personas con el genotipo 1, en 2011.

El tratamiento suele durar de 6 a 12 meses. Es importante tomar estos medicamentos exactamente como lo receta el médico. No deje de tomar estos medicamentos ni cambie la dosis (cantidad) que toma sin consultarlo con su médico primero. Pregunte a su médico si estos medicamentos podrían interactuar con otros que esté tomando.

Hable siempre con su médico antes de tomar cualquier remedio herbal o suplemento vitamínico. Estos podrían empeorar el daño al hígado e interactuar con sus medicamentos para la hepatitis C.

Una vez que termine el tratamiento, su médico ordenará un análisis de sangre para ver si se ha eliminado el virus de la hepatitis C. Si el virus de la hepatitis C no se encuentra en la sangre a los seis meses de concluido el tratamiento, el virus se habrá eliminado. Eso significa que es probable que el virus ya no regrese. Después de un tratamiento eficaz, aún puede volver a infectarse de hepatitis C. Es importante tomar precauciones para evitar infectarse nuevamente.

### ¿Qué dicen las investigaciones sobre la eficacia de los medicamentos para la hepatitis C crónica?

Los investigadores descubrieron que:

- El tratamiento doble con peginterferón alfa-2a parece ser igual de eficaz que el tratamiento doble con peginterferón alfa-2b.
- Al parecer, en las personas con el genotipo 1 el tratamiento triple permite obtener mejores resultados que el tratamiento doble.
- Entre las personas con el genotipo 1 que terminan el tratamiento triple, el virus de la hepatitis C se elimina de la sangre en 60 a 75 por ciento de los casos.
- Entre las personas con el genotipo 1 que terminan el tratamiento doble, el virus de la hepatitis C se elimina de la sangre en 40 a 50 por ciento de los casos.
- Entre las personas con el genotipo 2 ó 3 que terminan el tratamiento doble, el virus de la hepatitis C se elimina de la sangre en 60 a 80 por ciento de los casos (dependiendo del tiempo que dure su tratamiento).
- No existe suficiente investigación para saber con qué frecuencia el virus de la hepatitis C se elimina de la sangre después del tratamiento doble en personas con el genotipo 4, 5 ó 6.

### ¿Qué efectos secundarios pueden causar los medicamentos para la hepatitis C crónica?

La FDA lista los efectos secundarios siguientes con la combinación de un interferón y una ribavirina.

Los más frecuentes:

- Cansancio
- Dolor de cabeza
- Dolores musculares
- Fiebre
- Escalofríos
- Náusea y vómito
- Pérdida del apetito
- Irritación de la piel en el sitio de la inyección
- Pérdida de cabello

Más graves, pero menos frecuentes:

- Depresión grave
- Pensamientos suicidas
- Número bajo de glóbulos blancos (células que combaten infecciones)
- Problemas de la glándula tiroides
- Azúcar alta en la sangre
- Problemas de los nervios
- Problemas graves de los ojos
- Anemia (número bajo de glóbulos rojos, que llevan el oxígeno a todo el cuerpo)
- Más daño al hígado
- Infamación del páncreas o los intestinos
- Problemas pulmonares
- Salpullido u otras irritaciones graves de la piel
- Problemas con los dientes o encías
- Reacción alérgica grave (hinchazón de la cara, ojos, labios, lengua o garganta; dificultad para respirar; dolor de pecho)

Advertencia: La ribavirina puede causar defectos de nacimiento o muerte del feto. Las mujeres no deben tomar ribavirina si tienen posibilidad de embarazarse o desean hacerlo. La mujer debe evitar el embarazo si su pareja está tomando ribavirina. Antes de embarazarse, la mujer debe dejar pasar por lo menos 6 meses desde que ella o su pareja hayan dejado de tomar ribavirina.

Las personas con antecedente de enfermedad del corazón, deben ser vigiladas minuciosamente por sus médicos durante el tratamiento con ribavirina. La ribavirina puede producir anemia grave en algunas personas, lo que puede aumentar el riesgo de ataques al corazón.

La FDA lista los efectos secundarios siguientes para el boceprevir (Victrelis^®^):

- Cansancio
- Anemia
- Náusea
- Dolor de cabeza
- Paladar amargo

La FDA lista los efectos secundarios siguientes para el telaprevir (Incivek^®^):

- Cansancio
- Comezón o picazón
- Anemia
- Náusea y vómito
- Salpullido (puede ser grave y hasta potencialmente mortal en casos raros)
- Hemorroides
- Diarrea
- Picazón y molestia alrededor del ano
- Paladar amargo

### ¿Qué dice la investigación acerca de los efectos secundarios de los medicamentos para la hepatitis C crónica?

#### Tratamiento doble

- Las personas que toman tratamiento doble con peginterferón alfa-2a son más propensas a tener un número bajo de glóbulos blancos, salpullido y otros efectos secundarios graves, que las que toman el tratamiento doble con peginterferón alfa-2b.

#### Tratamiento triple con boceprevir (Victrelis^®^)

De las personas que reciben este tipo de tratamiento:

- 50 por ciento desarrollan anemia
- Hasta 5 por ciento desarrollan anemia grave
- 25 por ciento tienen un número bajo de glóbulos blancos
- Hasta 15 por ciento tienen un número muy bajo de glóbulos blancos

#### Tratamiento triple con telaprevir (Incivek^®^)

De las personas que reciben este tipo de tratamiento:

- Entre 25 por ciento y más de 75 por ciento desarrollan anemia
- Hasta 10 por ciento desarrollan anemia grave
- Entre 33 y 66 por ciento desarrollan salpullido
- Hasta 10 por ciento desarrollan salpullido grave

#### Comparación de los tratamientos doble y triple

De las personas que reciben este tipo de tratamiento:

- Las que toman el tratamiento triple corren un mayor riesgo de padecer de anemia que las que toman el tratamiento doble.
- Las que toman el tratamiento triple con telaprevir (Incivek^®^) corren un mayor riesgo de tener salpullido que las que toman el tratamiento doble.

### ¿Qué pasa si no funciona el tratamiento?

Si usted no responde a ninguno de los tratamientos disponibles, es posible que en el futuro haya otros nuevos que puedan ayudarle. Los científicos trabajan constantemente para desarrollar tratamientos que sean más eficaces y causen menos efectos secundarios.

### ¿Necesitaré un trasplante de hígado?

Si la hepatitis C crónica le causa insuficiencia hepática (del hígado), puede llegar a necesitar un trasplante de hígado. En esta operación, el cirujano sustituye el hígado enfermo con el hígado sano de un donante de órganos. Es posible que deba tomar medicamentos para la hepatitis C crónica aún después del trasplante, porque es común que la hepatitis C que permanece en el cuerpo infecte el hígado nuevo.

Las personas que necesitan un hígado nuevo a menudo tienen que esperar largo tiempo en una lista de trasplantes. No todas las personas inscritas en la lista obtendrán un hígado. Si llega a haber un hígado disponible, la cirugía para el trasplante puede tener riesgos graves, entre ellos la muerte.

### ¿Qué más puedo hacer para ayudar a proteger mi hígado?

Su médico puede sugerir otras formas de ayudar a proteger su hígado; por ejemplo:

- Evitar las bebidas alcohólicas o limitar la cantidad que toma
- Comer saludablemente
- Mantener un peso saludable
- Hacer suficiente ejercicio

### ¿Qué puedo hacer para prevenir infectar a otras personas?

La hepatitis C se transmite por la sangre. Para evitar infectar a otras personas, procure no compartir artículos que tengan contacto con su sangre, como el cepillo de dientes, las maquinillas de afeitar o las agujas para inyectar.

### ¿Dónde puedo encontrar más información?

Puede obtener más información sobre la hepatitis C y las opciones para su tratamiento en:

- La página web de los Centers for Disease Control and Prevention (Centros para el Control y la Prevención de Enfermedades): www.cdc.gov/hepatitis/HCV/PDFs/HepCLivingWithChronic.pdf (disponible sólo en inglés)
- La página web del Department of Veterans Affairs (Departamento de Asuntos de los Veteranos) de Estados Unidos: www.hepatitis.va.gov (disponible sólo en inglés)

## Tome una decisión

### ¿En qué cosas debo pensar?

Se deben considerar varias cosas al elegir un tratamiento para la hepatitis C crónica:

Usted y su médico deben hablar de:

- Si la hepatitis C crónica necesita tratarse inmediatamente o si el tratamiento puede esperar
- Qué tan eficaces pueden ser los medicamentos para tratar su genotipo de hepatitis C
- Qué plan de tratamiento sería mejor para usted y cómo puede el tratamiento afectar su estilo de vida
- Posibles efectos secundarios graves de los medicamentos
- Qué hará usted si los efectos secundarios se agravan demasiado como para seguir tomando el medicamento
- El costo de cada medicamento

### ¿Cuáles son los costos de los medicamentos para la hepatitis C crónica?

En la próxima página se indican los precios de mayoreo de los medicamentos para la hepaitis C crónica. Los precios de mayoreo son los precios que pagan las farmacias.

El costo que cada medicamento tenga para usted dependerá de su seguro médico, de la dosis (cantidad) que necesite y si el medicamento existe en forma genérica.

Precios de mayoreo de los interferones

Nombre del medicamento | Dosis | Nombre comercial | Costo del de marca por mes^*^
Peginterferón alfa-2a | 180 mcg por semana | Pegasys^®^ | $2,960
Peginterferón alfa-2b | 80–150 mcg por semana | Pegintron^®^ | $2,896–$3,194

* Los precios de la tabla son los precios promedio de mayoreo según el RED BOOK Online^®^.

Precios de mayoreo de la ribavirina

Nombre del medicamento | Dosis | Precio del genérico por mes^*^ | Nombre comercial | Costo del de marca por mes^*^
Ribavirina | 800-1,400 mg al día | 800 mg: $1,192 1,000 mg: $1,490 1,200 mg: $1,787 1,400 mg: $2,085 | Copegus^®^ | 800 mg: $2,166 1,000 mg: $2,708 1,200 mg: $3,249
Ribavirina | 800-1,400 mg al día | 800 mg: $1,192 1,000 mg: $1,490 1,200 mg: $1,787 1,400 mg: $2,085 | Rebetol^®^ | 800 mg: $1,272 1,000 mg: $1,590 1,200 mg: $1,908 1,400 mg: $2,226
Ribavirina | 800-1,400 mg al día | 800 mg: $1,192 1,000 mg: $1,490 1,200 mg: $1,787 1,400 mg: $2,085 | Ribasphere^®^ | 1,000 mg: $705 1,200 mg: $846

* Los precios de la tabla son los precios promedio de mayoreo según el RED BOOK Online^®^. Los precios del medicamento genérico son el valor medio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

Precios de mayoreo del boceprevir y el telaprevir

Nombre del medicamento | Dosis | Nombre comercial | Costo del de mar por mes^*^
Boceprevir | 800 mg tres veces al día | Victrelis^®^ | $6,052
Telaprevir | 750 mg tres veces | Incivek^®^ | $7,520

* Los precios de la tabla son los precios promedio de mayoreo según el RED BOOK Online^®^.

### Pregunte a su médico

- ¿Necesito tratar mi hepatitis C crónica inmediatamente o puedo esperar?
- Si decido esperar, ¿cuánto tiempo puedo dejar pasar antes de que deba iniciar el tratamiento? ¿Cómo sabremos cuándo tratar mi hepatitis C crónica?
- Si decido tratarme ahora, ¿qué opción de tratamiento cree que sería mejor para mí? ¿Por qué?
- ¿Cuánto tiempo deberé tomar el medicamento?
- ¿Cómo afectará el tratamiento mi capacidad para trabajar, viajar y hacer mis actividades diarias?
- ¿De qué efectos secundarios graves debo estar pendiente y cuándo debo avisarle si aparecen?
- ¿Puedo tomar otros medicamentos para aliviar algunos de los efectos secundarios?
- ¿Qué podemos hacer si los efectos secundarios se agravan demasiado y tengo que dejar de tomar el medicamento para la hepatitis C?
- ¿Afectarán los medicamentos para la hepatitis C a otros que tomo?
- ¿Los remedios herbales o los medicamentos sin receta, como los analgésicos, interactuarán con mi tratamiento o me afectarán el hígado?
- ¿Puedo tomar bebidas alcohólicas o me afectarán el hígado?
- ¿Qué debo hacer para no volver a infectarme de hepatitis C o adquirir otros tipos de hepatitis? ¿Debo ponerme la vacuna de hepatitis A o de hepatitis B?
- ¿De qué debo hablar con mi pareja o con mis familiares? ¿Necesitan ellos hacerse la prueba de hepatitis C?
- ¿Me ayudaría tener un grupo de apoyo mientras sigo el tratamiento?
- ¿Se están desarrollando otros tratamientos para la hepatitis C crónica que puedan ayudarme en el futuro?

### Otras preguntas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

### Fuente

La información de este resumen proviene del informe Treatment for Hepatitis C Virus Infection in Adults: A Comparative Effectiveness Review (Tratamiento de la infección por virus de la hepatitis C en adultos: revisión de eficacia comparada). El informe fue producido por el Oregon Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Oregon), con patrocinio de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite http://www.effectivehealthcare.ahrq.gov/hepctreatment.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish. Puede obtenerse más información de los Centers of Disease Control and Prevention, en www.cdc.gov/hepatitis/HCV/PDFs/HepCLivingWithChronic.pdf.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con hepatitis C crónica.

Los resultados de este informe se publicaron también en el artículo “Comparative Effectiveness of Antiviral Treatment for Hepatitis C Virus Infection in Adults: A Systematic Review” (Comparación de la efectividad del tratamiento antiviral para la infección por el virus de la hepatitis C en adultos: revisión sistemática), el 27 de noviembre de 2012 en la revista Annals of Internal Medicine.

Esta guía fue traducida de la publicación en inglés titulada Treating Chronic Hepatitis C: A Review of the Research for Adults.

* En este resumen, el término “médico” se refiere a cualquier profesional de atención médica que pueda atenderle, lo que incluye su hepatólogo u otro médico, enfermera o asistente médico.

* Esta información proviene de la página web de los Centers for Disease Control and Prevention (Centros para el Control y la Prevención de Enfermedades): www.cdc.gov/hepatitis/HCV (disponible en inglés)