# Conozca sobre la radioterapia en el cáncer de cabeza y cuello

Guía para adultos y personas que ayudan a su cuidado

## ¿Es esta guía apropiada para mí?

### Es apropiada si

- Le han diagnosticado cáncer de cabeza y cuello.
- Su médico ha recomendado la radioterapia para tratar ese cáncer.

Esta guía es para ayudarle a decidir el tipo de radioterapia que debe escoger para tratar su cáncer de cabeza y cuello.

### ¿Qué cubre esta guía?

La radiación puede administrarse con un aparato que está afuera del cuerpo (lo que se llama “radioterapia de haz externo”) o que se coloca dentro del cuerpo (lo que se llama “braquiterapia”).

Esta guía sólo abarca la radioterapia de haz externo.

Esta guía explica las diferencias entre cuatro tipos de radioterapia y los posibles efectos secundarios.

Esta guía no cubre otros tipos de tratamiento para el cáncer de cabeza y cuello que tal vez esté recibiendo o haya recibido, como la quimioterapia o la cirugía. Tampoco cubre los tratamientos del cáncer cerebral o cáncer de tiroides.

De no estar seguro de que esta guía sea apropiada para usted, pregunte a su médico, enfermera u otro profesional de atención médica.

### ¿De dónde proviene la información?

La información de esta guía se deriva de una revisión de muchos estudios diferentes sobre radioterapia para el cáncer de cabeza y cuello.

No se basa en sólo un estudio, sino en muchos, que son considerados en conjunto por un equipo de investigadores, médicos y otros expertos.

## Conozca su enfermedad

### ¿Qué es el cáncer de cabeza y cuello?

La mayoría de los tipos de cáncer de cabeza y cuello se inician en las células que tapizan las cavidades abiertas de la cabeza y el cuello, como los senos paranasales, la cavidad nasal, la boca o la garganta. Otros tipos de cáncer de cabeza y cuello ocurren en las glándulas salivales. Estas glándulas producen el líquido que se conoce como “saliva” y que mantiene húmedas la boca y la garganta. El cáncer cerebral y el cáncer de tiroides no se clasifican como cáncer de cabeza y cuello.

De acuerdo con el National Cancer Institute (Instituto Nacional del Cáncer), el cáncer de cabeza y cuello representa entre 3 y 5 por ciento de todos los casos de cáncer en Estados Unidos. Estos tipos de cáncer son más frecuentes en hombres y en personas mayores de 50 años. Cada año, cerca de 47,560 hombres y mujeres desarrollan cáncer de cabeza y cuello en Estados Unidos. El consumo de tabaco y alcohol es un factor de riesgo frecuente que ocasiona el desarrollo de este tipo de cáncer.

### ¿Cómo se trata el cáncer de cabeza y cuello?

Para tratar el cáncer de cabeza y cuello los médicos pueden usar varios métodos. Por ejemplo:

- Cirugía, en la cual se elimina todo o una parte del tumor o de las células cancerosas.
- Quimioterapia, en la cual se usan ciertos medicamentos para destruir las células cancerosas.
- Radioterapia, en la cual se aplica ondas de energía para destruir las células cancerosas del tumor y su periferia.
  A menudo, estos tratamientos se utilizan juntos. Esta guía es sólo sobre radioterapia.

## Conozca la radioterapia

### ¿Qué es la radioterapia?

#### Cómo la radiación trata su cáncer

Se aplica radiación de alta energía al tumor o las células cancerosas.

La radioterapia funciona de dos formas:

- La radiación puede detener o retardar el desarrollo del cáncer.
- La radiación puede causar la reducción de los tumores, disminuir algunos síntomas y aliviar el dolor.

La radioterapia no destruye inmediatamente las células cancerosas. Puede que necesite varios días o semanas de tratamiento con radiación antes que estas células empiecen a morir. Las células cancerosas seguirán muriendo durante semanas o meses después de terminada la radioterapia.

#### La radioterapia empieza con un plan

Sus médicos elaborarán un plan detallado de radioterapia para su tratamiento. Dicho plan incluye:

- Hacia dónde se deben apuntar los haces de radiación.
- Cuánta radiación usted debe recibir.

La meta del plan es aplicar la cantidad correcta de radiación para que el tumor deje de crecer o se reduzca. Los médicos deben protegerlo de cualquier daño causado por la radiación, especialmente a las células alrededor del tumor.

#### Diferentes sistemas para administrar la radiación

Los médicos utilizan distintos sistemas e instrumentos para preparar el plan de tratamiento y administrarle radioterapia. El método que puede que su médico utilice para dirigirse al tumor, apuntar los haces de radiación y cambiar la potencia del haz mientras lo aplica ha cambiado con el tiempo. El uso de potencias distintas del haz puede ayudar a protegerlo de los efectos secundarios de la radiación.

### ¿Qué efectos secundarios tiene la radioterapia?

#### Cada persona es distinta

La radioterapia puede dañar las células sanas y normales que están cerca o alrededor del cáncer. El daño puede causar efectos secundarios. Estos efectos secundarios pueden variar mucho según la persona. Los efectos secundarios que usted tenga pueden depender de:

- La dosis y el tipo de radiación que se usen.
- El lugar en que esté su cáncer.
- La etapa de su cáncer.
- Su edad.

#### Tipos de efectos secundarios

Los efectos secundarios pueden aparecer a las 2 semanas de la primera sesión de radioterapia o mucho después y pueden ser:

- Irritación de boca (que se siente como pequeños cortes o úlceras en la boca).
- Boca seca (llamada también “xerostomía”).
- Dolor o dificultad para tragar.
- Cambios en el sentido del gusto o el olfato.
- Cambios en el sonido de su voz.
- Rigidez de la mandíbula y deterioro del hueso mandibular.
- Cambios en la piel.
- Cansancio.

#### ¿Qué impacto pueden tener estos efectos secundarios?

La radioterapia no causa dolor cuando se administra. Sin embargo, algunos de los efectos secundarios pueden causar dolor o afectar su calidad de vida, aun cuando la radiación ayude a detener o a retrasar su cáncer. Algunos efectos secundarios duran solamente unos días. Otros pueden durar semanas, meses o más.

Es posible que algunos efectos secundarios, como la boca seca (xerostomía), nunca mejoren. La saliva es útil para muchas cosas. Es necesaria para ayudarle a tragar los alimentos cuando come. La saliva ayuda también a protegerlo de la caries dental y enfermedades de la lengua y las encías, al evitar que las bacterias se alojen en sus dientes, lengua y encías. La saliva incluso nos ayuda a hablar.

## Conozca sus opciones

### ¿Qué diferencias existen entre los sistemas de radiación?

Los médicos cuentan con cuatro sistemas de radiación de haz externo para tratar su cáncer. Los primeros tres se han utilizado con éxito durante varios años para tratar el cáncer de cabeza y cuello.

- El sistema más antiguo se llama radioterapia bidimensional o 2DRT. Este sistema apunta al tumor utilizando una imagen de dos dimensiones —muy parecido a un dibujo o fotografía. Los haces se pueden dirigir solamente en ciertos ángulos y no cambian de potencia mientras se aplican. La 2DRT no se usa tanto como los sistemas más modernos.
- Un sistema más moderno se llama radioterapia tridimensional conformacional o 3DCRT. Este sistema utiliza imágenes tridimensionales que permiten a los médicos apuntarle mejor al tumor. Las imágenes son creadas con un aparato de tomografía computadorizada (CT) o de resonancia magnética (MRI). Los haces pueden dirigirse en más ángulos que con la 2DRT, para limitar la cantidad de radiación que llega a las partes normales alrededor del tumor.
- Un sistema más nuevo se llama radioterapia de intensidad modulada o IMRT. Este sistema es similar a la 3DCRT, pero el médico puede ajustar la cantidad de radiación que usted recibe de cada haz. Con eso se intenta reducir lesiones a las partes sanas que rodean el tumor.
- Otro sistema usa un tipo distinto de haz de energía para tratar el tumor. Este sistema se llama radioterapia de haz protónico o PBRT. Se tiene muy poca información sobre la eficacia de este tipo de radioterapia y no se usa mucho.

### ¿Qué tipo de radioterapia es el más eficaz para mi cáncer?

- Los médicos no saben si un tipo de radioterapia es más eficaz que otros para detener o retardar el avance de su cáncer de cabeza y cuello.
- Los médicos no saben si algún tipo de radioterapia específica controlará mejor su cáncer o le ayudará a vivir más.

### ¿Qué tipo puede tener menos efectos secundarios?

- Cierta evidencia existente indica que la IMRT causa menos daño a las glándulas productoras de saliva en comparación con la 2DRT o la 3DCRT. Los resultados iniciales de un estudio reciente, que examinó a pacientes un año después del tratamiento, indicaron que el efecto secundario de “boca seca” se presentó con menos frecuencia en las personas que se trataron con IMRT que las tratadas con 2DRT o 3DCRT.
- Aunque los médicos piensan que la IMRT puede ayudar a evitar el daño a otros órganos normales de la cabeza y el cuello —como los ojos, el cerebro y otras glándulas— no están totalmente seguros de esto.
- Puede ser importante la habilidad y experiencia de sus médicos en el uso de cada tipo de radioterapia. Los estudios actuales se efectuaron en centros asociados con universidades y escuelas médicas. Los médicos no saben si los resultados son diferentes en otros tipos de centros médicos.
- Los médicos no saben si los efectos secundarios de la PBRT difieren de los otros tres tipos de radioterapia.

### Tome una decisión

#### ¿Qué preguntas debo hacerle a mi médico?

1. ¿Qué efectos secundarios puedo tener con más probabilidad con la radioterapia, cuándo pueden aparecer y cuánto tiempo pueden durar?
2. ¿Qué tipos de radioterapia se pueden usar en mi caso?
3. ¿Cuánta experiencia tienen los médicos y el personal médico de aquí con cada tipo de radioterapia?
4. ¿Cómo se aseguran de que el tumor y los tejidos a su alrededor reciban la cantidad correcta de radiación?

Otras preguntas para su médico:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva del informe Comparative Effectiveness and Safety of Radiation Therapy Treatments for Head and Neck Cancer (Comparación de la efectividad y seguridad de los métodos de radioterapia en el cáncer de cabeza y cuello). Fue producida por el Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro de Evaluación Tecnológica de la Blue Cross and Blue Shield Association) mediante el financiamiento de la Agency for Healthcare and Research Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ, por sus siglas en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov. Se obtuvo información adicional del National Cancer Institute (Instituto Nacional del Cáncer) (www.cancer.gov). Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas en la Universidad de Medicina de Baylor) de Houston, Texas.