# Hormona del crecimiento humano para los niños con fibrosis quística

Revisión de la investigación para padres y personas que ayudan al cuidado

## Acerca de esta guía

### ¿Para quién es esta guía?

Esta guía es para cualquier persona encargada de cuidar a un niño o adolescente con fibrosis quística (CF, por su sigla en inglés) y ayudará a tomar decisiones sobre el tratamiento. Tal vez usted ya haya oído hablar del uso de la hormona del crecimiento humano (HGH, por su sigla en inglés) en niños con CF y quiera saber más sobre las investigaciones.

### ¿Para qué se revisan las investigaciones sobre la hormona del crecimiento humano?

Aunque la HGH no trata de forma directa la CF, los investigadores han querido saber si un aumento en la estatura o el peso con el uso de la HGH podría mejorar la respiración u otros aspectos de la salud.

### ¿Qué no cubre esta guía?

Esta guía no cubre muchas de las terapias y tratamientos de la CF, incluidos otros tratamientos que ayudan a subir de peso a los niños con CF. La guía tampoco abarca el uso de HGH en los adultos con CF.

### ¿De dónde proviene la informacíon?

La información proviene de una revisión de 79 estudios clínicos. Investigadores independientes, patrocinados por la Agency for Healthcare and Research Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés) revisaron los resultados del uso de la HGH en niños con CF. Las preguntas de investigación y los resultados de investigación publicados se sometieron a evaluación por expertos, revisión por colegas y a la opinión del público. El informe completo puede leerse en http://www.effectivehealthcare.ahrq.gov/hgh.cfm (disponible sólo en inglés).

## Conozca sobre la fibrosis quística

### ¿Qué es la fibrosis quística?

- La CF es una enfermedad hereditaria que afecta a cerca de 30,000 niños y adultos en Estados Unidos.
- La CF se observa con mayor frecuencia en niños de raza blanca, pero puede afectar a niños de cualquier raza o grupo étnico.
- La CF se produce cuando el niño hereda un gen anormal de cada uno de sus padres, aun cuando ninguno de los dos tenga la enfermedad.
- El gen anormal causa que el cuerpo del niño produzca un moco espeso, pegajoso. Ese moco puede:
  □ Taponar los pulmones, y dificultar la respiración.
  □ Obstruir el páncreas u otros órganos que ayudan a digerir los alimentos.
  □ Alojar microbios causantes de infección.

### ¿Cómo afecta al crecimiento la fibrosis quística?

La CF puede impedir que los niños obtengan de los alimentos todas las calorías y nutrientes que necesitan. Por esa razón, la estatura y el peso de muchos niños con CF están debajo del promedio normal para su edad.

Algunas investigaciones indican que una estatura y peso por debajo de lo normal pueden aumentar el riesgo de que se produzcan otros problemas relacionados con la CF y que el niño viva menos tiempo.

## Conozca sobre la hormona del crecimiento humano

### ¿Qué es la hormona del crecimiento humano?

La HGH es una de muchas hormonas producidas por la glándula pituitaria (o hipófisis), situada inmediatamente debajo del cerebro. Las hormonas son mensajeros químicos que envían señales a las células del cuerpo. Algunos mensajes les indican a las células cómo utilizar los alimentos o producir más células. La hormona del crecimiento les envía a las células de los músculos, huesos y órganos corporales la señal para que crezcan.

### ¿Cómo se usa la hormona del crecimiento humano como medicamento?

Para usarla como medicamento, la hormona del crecimiento humano se elabora en un laboratorio. Esta forma de la hormona se llama “somatropina” u “hormona del crecimiento humano recombinante” (rhGH en inglés).

La somatropina se administra en el hogar, en la forma de una inyección diaria. Está aprobada por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos para tratar problemas del crecimiento en niños.

## Conozca las investigaciones sobre la hormona del crecimiento

### ¿Ofrece beneficios?

Las investigaciones realizadas no demuestran que tomar somatropina ayude a aumentar la duración o la calidad de la vida de los niños o adolescentes con CF.

Se observaron pequeños cambios en los niños cuando se agregó somatropina durante 6 a 12 meses a otros tratamientos. Estos niños:

- Pasaron en el hospital entre una y dos noches menos cada año que los niños que no tomaron somatropina.
- Crecieron poco más de 1 pulgada y aumentaron unas 3 libras más que los niños que no tomaron somatropina.
- Mostraron aumentos pequeños en varias pruebas de la función pulmonar, aunque no en la prueba que los investigadores consideran relacionada con el tiempo de vida.

### ¿Existen riesgos?

- Muy pocos niños con CF que han tomado somatropina en estudios han tenido que interrumpirla a causa de efectos secundarios como, por ejemplo, una reacción a la inyección.
- Las personas con CF tienen mayor riesgo de desarrollar diabetes relacionada con CF. Los investigadores no saben si la somatropina aumenta el riesgo de que el niño desarrolle diabetes relacionada con CF.
- Los adultos con CF tienen mayor riesgo de desarrollar ciertos tipos de cáncer del aparato digestivo o del hígado. Los investigadores no saben si las personas con CF que han utilizado somatotropina tengan un mayor riesgo de desarrollar cáncer.

### ¿Cuáles son los costos?

El costo que tendrá para usted el tratamiento con somatropina depende de varias cosas, por ejemplo:

- Su seguro médico.
- La cantidad (dosis) del medicamento y con qué frecuencia necesite tomarlo el niño.
- El costo real del medicamento para el hospital o farmacia.

Es posible que el seguro médico no cubra el costo de la somatropina en niños con CF. El tratamiento con hormona del crecimiento humano es costoso. El costo de comprar la somatropina suficiente para tratar a un adolescente típico puede ser de decenas de miles de dólares cada año.

### Pregunte a su médico

Si esta usted considerando agregar somatropina a otros medicamentos que ya usa su hijo para tratar la CF, le recomendamos hablar con el médico del niño sobre la información que ofrece esta guía.

#### Preguntas para el médico de su hijo

1. ¿Qué piensa usted de las investigaciones sobre la hormona del crecimiento humano en los niños con CF?
2. ¿Se necesita aumentar la estatura y el peso de mi hijo? De ser así, ¿con qué otras opciones contamos, además de la somatropina?
3. ¿Qué piensa usted de los efectos secundarios a largo plazo de la somatropina?

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuentes

La información de esta guía proviene del informe Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis (‘Eficacia de la hormona del crecimiento humano recombinante de [rhGH] en el tratamiento de pacientes con fibrosis quística’). Fue producida por el Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia) de la University of Connecticut-Hartford Hospital, mediante el patrocinio de la Agency for Healthcare and Research Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés) Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa de Cuidados Efectivos de la Salud), visite http://www.effectivehealthcare.ahrq.gov/hgh.cfm (disponible sólo en inglés).

Esta guía abreviada fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas en la Universidad de Medicina de Baylor de Houston, Texas). Esta guía se desarrolló con la ayuda de padres y cuidadores de niños con fibrosis quística y de adultos con la enfermedad.