# Métodos para administrar insulina y medir el azúcar en la sangre

Revisión de las investigaciones para niños, adolescentes y adultos con diabetes

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Su médico^*^ le ha dicho que usted tiene diabetes tipo 1 o tipo 2 y que debe usar insulina para controlar su azúcar en la sangre.
- Usted mide su nivel de azúcar en la sangre durante el día para saber cuánta insulina debe administrarse.

### No es apropiada si

- Su médico le ha dicho que tiene diabetes, pero que no necesita usar insulina.
- Su médico le ha dicho que tiene diabetes gestacional. Es un tipo de diabetes que se presenta en las mujeres embarazadas que no tenían diabetes antes del embarazo.

### ¿Qué aprenderé con este resumen?

Este resumen explica lo que dicen las investigaciones acerca de varias formas de medir el azúcar en la sangre y de administrar insulina. Describe lo que saben los investigadores sobre cómo se compara cada opción con las demás, y para ayudarle a controlar su nivel de azúcar en la sangre.

Este resumen no aborda otras formas de tratar la diabetes, como tomar pastillas, cambiar la alimentación o hacer ejercicio. El resumen tampoco incluye toda la información básica sobre la diabetes que tal vez quiera usted conocer si acaba de enterarse de que tiene diabetes. Para obtener información general acerca de la diabetes, visite http://www.nlm.nih.gov/medlineplus/spanish/diabetes.html.

### ¿De dónde proviene la información de este resumen?

La información de este resumen proviene de la revisión de 41 estudios publicados hasta julio de 2011 en los que se compararon formas de medir el azúcar en la sangre y de administrar insulina, en personas con diabetes. La revisión fue financiada por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal. El informe completo se puede leer en www.effectivehealthcare.ahrq.gov/glucose.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la diabetes?

La diabetes (llamada también “diabetes mellitus”) es una condición que ocurre cuando el cuerpo tiene dificultad para controlar el nivel de azúcar (o glucosa) en la sangre. Esto ocasiona que el azúcar en la sangre aumente demasiado.

Existen dos tipos principales de diabetes: El tipo que usted tiene depende de las razones que causan que tenga el azúcar alta en la sangre.

- La diabetes tipo 1 significa que el cuerpo fabrica muy poca o nada de insulina (sustancia que el cuerpo necesita para utilizar el azúcar). Los médicos también pueden llamar “insulinodependiente” a esta diabetes. La persona debe usar insulina para controlar este tipo de diabetes.
- La diabetes tipo 2 significa que el cuerpo no puede producir suficiente insulina o las células de su cuerpo no utilizan bien la insulina. Los médicos también pueden llamar “no insulinodependiente” o “resistente a la insulina” a este tipo de diabetes. Algunas personas con este tipo de diabetes pueden controlar su azúcar en la sangre por medio de dieta, ejercicio y medicamentos. Otros probablemente necesitarán usar insulina.

### ¿Qué tan frecuente es la diabetes?

Actualmente, 8 de cada 100 personas en Estados Unidos (cerca de 26 millones de personas) tienen diabetes. Se calcula que esta cifra aumentará a casi 10 de cada 100 personas antes de 2050.

De cada 100 personas con diabetes:

- Entre 5 y 10 tienen el tipo 1.
- Entre 90 y 95 tienen el tipo 2.

### ¿Por qué es importante controlar mi azúcar en la sangre?

Usted puede controlar los efectos que tiene la diabetes en su salud si controla su azúcar en la sangre. Controlar el azúcar en la sangre significa asegurarse de que su nivel de azúcar no aumente demasiado.

Entre los problemas graves de salud que causa el azúcar alta (la condición llamada “hiperglucemia”) están:

- Endurecimiento de las arterias
- Enfermedades del corazón
- Derrame cerebral
- Enfermedad de los riñones
- Ceguera
- Más infecciones
- Pérdida del pie o de los dedos de la mano o del pie, a causa de mala circulación e infecciones

El tratamiento puede ayudar a disminuir el azúcar alta en la sangre. Si su azúcar en la sangre baja demasiado (condición llamada “hipoglucemia”), podrá sentirse mareado, débil o desmayarse (perder el sentido). Si no se trata de inmediato, la hipoglucemia puede causar incluso la muerte. Es importante vigilar su azúcar en la sangre de manera que no baje demasiado. Algunas personas con diabetes pueden beber jugo de naranja o comer un dulce o caramelo cuando su nivel de azúcar baja demasiado. Es importante que hable de la hipoglucemia con su médico.

Si es usted mujer y tiene diabetes, el embarazo puede hacer que sea más difícil controlar su nivel de azúcar en la sangre. Es importante que controle su azúcar durante el embarazo para que usted y su bebé se mantengan sanos.

## Conozca sus opciones

### Medición del azúcar en la sangre

#### ¿Cómo sé qué cantidad de azúcar tengo en la sangre?

Hay dos tipos de pruebas que indican su nivel de azúcar en la sangre:

- Prueba de A1C
- Prueba de azúcar en sangre

Los médicos usan un análisis de sangre especial, llamado prueba de A1C, para ver qué tan alto ha sido el nivel de azúcar en la sangre durante los últimos 3 meses. Tener un nivel de A1C de 7 por ciento o menos significa que el azúcar en la sangre se ha controlado bien durante los últimos 3 meses.^**^

Cuando se usa insulina, es necesario hacerse un tipo distinto de prueba, llamada prueba de azúcar en la sangre—que a menudo requiere pincharse un dedo—para ayudarle a ajustar la cantidad de insulina que se administra durante el día. Esta prueba mide la cantidad de azúcar en la sangre en un momento determinado. Esta medición se expresa en miligramos por decilitro (mg/dL). Los niveles normales de azúcar en la sangre en personas que no tienen diabetes son:

- Entre 70 y 130 mg/dL antes de las comidas^**^
- Menos de 180 mg/dL 2 horas después de las comidas^**^

Hable con su médico para establecer una meta para su nivel de azúcar en la sangre.

#### ¿Cómo puedo medir mi nivel de azúcar con la prueba de azúcar en sangre?

Hay dos maneras de medir su nivel de azúcar en la sangre:

- Automedición
- Monitoreo automático

##### Automedición

Puede usar un medidor de glucosa para medir su azúcar en la sangre. En una tira de prueba, se pone una gotita de sangre obtenida de su dedo o antebrazo. El medidor lee la tira y presenta un número en la pantalla con el resultado. Algunos medidores pueden almacenar los resultados durante varios meses. Hay muchos tipos y estilos de medidores de glucosa en la sangre.

##### Monitoreo automático

Un sistema de monitoreo continuo de glucosa en tiempo real lleva un registro automático de los cambios del nivel de glucosa durante todo el día y la noche. Es un aparato pequeño que se lleva en el cinturón o correa. El dispositivo tiene sensores que se fijan al abdomen y una aguja pequeña que se sujeta con cinta adhesiva. El sistema mide su nivel de azúcar con una frecuencia de cada 1 a 5 minutos. El monitor muestra sus lecturas de azúcar en la sangre y puede guardarlas para que las revise el médico. Los resultados pueden ayudarles a usted y al médico a ajustar la cantidad correcta de insulina.

Los sensores de los monitores automáticos tienen que sustituirse regularmente. Tal vez tenga que cambiar de lugar los sensores en el abdomen para evitar irritación o infecciones.

Es posible que los médicos sugieran el monitoreo automático solamente a las personas que tienen dificultad para controlar su azúcar en la sangre y a las que no puedan darse cuenta cuando el azúcar se les baja demasiado.

El monitoreo automático puede que no sea tan exacto como la automedición. Si utiliza el monitoreo automático, aún necesitará automedirse regularmente para verificar que las lecturas sean exactas. Si su nivel de azúcar en la sangre cambia, puede tardar entre 5 ó 10 minutos en aparecer en el monitor. Pregunte a su médico cómo puede esto afectar la cantidad de insulina que se administra.

### ¿Qué dicen las investigaciones sobre la automedición en comparación con el monitoreo automático?

- Los niños, adolescentes y adultos con diabetes tipo 1 que usan monitores automáticos:
  - Tienen menos hiperglucemia (azúcar alta en la sangre) y niveles más bajos de A1C que los que usan la automedición.
  - Tienen hipoglucemia (azúcar demasiado baja en la sangre) casi durante la misma cantidad de tiempo que los que usan la automedición.
  - Pueden tener casi la misma calidad de vida que los que usan la automedición, pero no existe suficiente investigación para saberlo con certeza.
- No existe suficiente investigación para comparar el monitoreo automático con la automedición en personas con diabetes tipo 2 o en mujeres embarazadas que tenían diabetes tipo 1 antes de embarazarse.

### Administración de insulina

#### ¿De qué maneras me puedo administrar la insulina?

Hay dos formas de administrarse insulina:

- Inyecciones
- Bombas de insulina

##### Inyecciones

Usted puede inyectarse la insulina de dos maneras:

- Use una jeringa y mida la cantidad determinada de insulina.
- Use plumas especiales que vienen con la insulina precargada. Estas plumas le permiten por medio de “clics” administrarse la cantidad de insulina que necesita.

Es posible que tenga que cambiar el lugar del cuerpo donde introduce la aguja, para evitar que se irrite o se formen moretones.

##### Bombas de insulina

Una bomba de insulina es un dispositivo pequeño con un tubo conectado a una aguja que se coloca dentro de la piel del abdomen. La aguja se mantiene fija con cinta adhesiva. Tal vez necesite cambiar la aguja de lugar en el abdomen para evitar irritación e infecciones. Usted fija la cantidad de insulina que la bomba debe administrarle. Así, el dispositivo va administrando la insulina durante el día o la noche. Usted puede usar la bomba también para administrarse insulina adicional durante las comidas o durante otras horas.

Hay dos tipos de bombas de insulina:

- Las bombas que usted programa de acuerdo con las lecturas de un medidor de glucosa.
- Las bombas que reciben lecturas de un monitor automático continuo. Éstas se llaman “bombas con sensor incorporado”. El monitor envía lecturas a la bomba y usted usa luego esas lecturas para ajustar la cantidad de insulina que necesita que administre la bomba.

#### ¿Qué dicen las investigaciones sobre la autoinyección (inyectarse uno mismo) en comparación con las bombas de insulina?

- Los niños o adolescentes con diabetes tipo 1 que usan bombas de insulina:
  - Disminuyen sus niveles de A1C casi en igual cantidad que aquellos que se autoinyectan.
  - Tienen una posibilidad de subir de peso, una calidad de vida y un riesgo de hipoglucemia (azúcar en sangre demasiado baja) similar al de aquellos que se autoinyectan, pero no existe suficiente investigación para saberlo con certeza.
- Los adultos con diabetes tipo 1 que usan bombas de insulina:
  - Tienen niveles de A1C más bajos que los que se autoinyectan.
  - Tienen una posibilidad de subir de peso, una calidad de vida y un riesgo de hipoglucemia similar al de aquellos que se autoinyectan, pero no existe suficiente investigación para saberlo con certeza.
- Los adultos con diabetes tipo 2 que usan bombas de insulina:
  - Disminuyen sus niveles de A1C casi en igual cantidad que aquellos que se autoinyectan.
  - Tienen una posibilidad de subir de peso y un riesgo de hipoglucemia (azúcar en sangre demasiado baja) similar al de aquellos que se autoinyectan, pero no existe suficiente investigación para saberlo con certeza.
- Al parecer, las bombas de insulina y las inyecciones fueron igual de eficaces para mejorar los niveles de A1C en mujeres embarazadas que tenían diabetes tipo 1 antes de embarazarse, pero no existe suficiente investigación para saberlo con certeza.

#### ¿Qué dicen las investigaciones sobre la eficacia de las bombas con sensor incorporado para controlar el azúcar en la sangre?

Los niños y adultos con diabetes tipo 1:

- Tienen menos hiperglucemia (azúcar alta en la sangre) y niveles más bajos de A1C que los que usan la automedición.
- Tienen hipoglucemia casi la misma cantidad de tiempo que los que usan la automedición.
- Pueden tener la misma probabilidad de subir de peso que los que usan la automedición, pero no existe suficiente investigación para saberlo con certeza.

## Tome una decisión

### ¿En qué cosas debo pensar?

Se deben considerar varias cosas al decidir cuál es la mejor manera de medirse el azúcar en la sangre o de administrarse insulina.

Hable con su médico sobre:

- Qué tan bien funciona cada opción para el tipo de diabetes que usted tiene.
- Qué tan bien usted ha podido controlar su azúcar en la sangre durante el último año.
- Cómo se manejan los dispositivos.
- Sus preferencias para medirse el azúcar en la sangre o administrarse insulina.
- Qué opción se adapta mejor a su estilo de vida y sus actividades diarias.
- Qué tan cómodo le parece usar un monitor automático, inyectarse o usar una bomba de insulina.
- Si su plan de seguro cubrirá el costo del aparato.

### ¿Cuánto cuestan estos dispositivos?

El costo para usted de estos aparatos depende de su plan de seguro. También deberá comprar cualquier componente de los aparatos que deba reponerse (como los sensores), los suministros que se utilicen (como las tiras de prueba) y la cantidad necesaria de insulina.

#### Monitores

- La automedición es la opción menos costosa.
- Los monitores son mucho más caros. Pueden costar hasta $1,500.^***^

#### Administración de insulina

- Las jeringas son la opción menos costosa. El costo depende de la cantidad que contenga el paquete.
- Las plumas son más caras que las jeringas.
- Las bombas son la opción más costosa. Pueden costar hasta $7,800.^***^

### Pregunte a su médico

- ¿Considera usted que mi nivel de azúcar en la sangre está bien controlado?
- ¿Hay algo que deba cambiar para controlar mejor mi diabetes?
- ¿Me ayudaría un monitor continuo o una bomba de insulina a controlar mi azúcar en la sangre?
- ¿Qué más puedo hacer para mantener mi azúcar en la sangre en un nivel saludable?

#### Otras preguntas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

#### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Methods for Insulin Delivery and Glucose Monitoring: A Comparative Effectiveness Review (Métodos para la administración de insulina y el monitoreo de glucosa: revisión de eficacia comparada), de julio de 2012.

El informe fue producido por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Johns Hopkins) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o si desea más información sobre AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite la página www.effectivehealthcare.ahrq.gov/glucose.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con diabetes tipo 1 y tipo 2.

Esta guía fue traducida de la publicación en inglés titulada Methods for Delivering Insulin and Monitoring Blood Sugar: A Review of the Research for Children, Teens, and Adults With Diabetes.

* En este resumen, el término “médico” se refiere a los profesionales de atención médica que pueden atenderlo, incluidos su médico, endocrinólogo, educador de diabetes, enfermera o asistente médico.

** Esta información proviene de la página web del National Institute of Diabetes and Digestive and Kidney Diseases/National Institutes of Health (Instituto Nacional de Diabetes y Enfermedades Digestivas y del Riñón/Institutos Nacionales de la Salud): http://www.diabetes.niddk.nih.gov/spanish/pubs/type1and2/what.aspx.

*** Los precios son el promedio de los precios de mayoreo que aparecen en el RED BOOK Online^®^.