# Tratamientos para el glaucoma de ángulo abierto

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Sí, esta información es para usted si

- Su oftalmólogo (médico de la vista) le ha dicho que tiene glaucoma de ángulo abierto, una condición de los ojos que produce pérdida de la vista.
- Su oftalmólogo ha sugerido el uso de medicamentos, cirugía con láser o cirugía convencional para tratar el glaucoma.

### No, esta información puede no ser útil para usted si

- Su oftalmólogo le ha dicho que tiene otra forma de glaucoma, como el glaucoma de ángulo cerrado, juvenil, congénito, traumático, neovascular, resistente o inflamatorio.
- Su oftalmólogo no le ha dicho que tenga glaucoma de ángulo abierto o no le ha sugerido iniciar tratamiento para esta condición.

### ¿Qué aprenderé con este resumen?

Este resumen le informará sobre los medicamentos, la cirugía con láser y la cirugía convencional para tratar el glaucoma de ángulo abierto. Le explicará lo que dicen las investigaciones sobre la eficacia de estos tratamientos y sus posibles efectos secundarios. Usted puede utilizar esta información para hablar con su oftalmólogo sobre el tratamiento que pueda ser más apropiado para usted.

Nota: Las investigaciones para este resumen se realizaron solamente con personas de 40 años y mayores.

### ¿De dónde viene esta información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés), organismo de investigación del gobierno federal, revisaron 109 estudios sobre tratamientos para el glaucoma de ángulo abierto publicados hasta octubre de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe, en inglés, se puede leer en: www.effectivehealthcare.ahrq.gov/glaucomatreatment.cfm. (disponible sólo en inglés)

## Conozca su condición

### ¿Qué es el glaucoma de ángulo abierto?

El glaucoma de ángulo abierto es uno de varios tipos de glaucoma (una condición que causa pérdida de la vista). El glaucoma es consecuencia de un daño al nervio óptico (el nervio que transmite las imágenes al cerebro). Con el tiempo, este daño puede hacer que pierda la capacidad de ver.

El glaucoma de ángulo abierto se desarrolla lentamente y la mayoría de las personas no notan ningún síntoma. Su oftalmólogo puede examinarlo para ver si se está dañando su nervio óptico. El glaucoma suele afectar ambos ojos, pero uno de ellos puede estar peor que el otro.

Un primer síntoma de glaucoma que puede notar es la dificultad para la visión lateral (la llamada “visión periférica”). También puede resultarle difícil ver las cosas con luz brillante o cambiar entre la luz y la oscuridad.

Sin tratamiento, su campo visual (el espacio que abarca la vista) se va reduciendo hasta que ya no puede ver. Su oftalmólogo puede hacer pruebas para detectar el glaucoma. Por eso es importante que visite regularmente a su oftalmólogo.

### ¿Qué causa el glaucoma de ángulo abierto?

El glaucoma de ángulo abierto es consecuencia de un daño a su nervio óptico. Una posible causa de daño al nervio óptico es un aumento de la presión interna de los ojos. La sensibilidad de los nervios ópticos al aumento de la presión es mayor en unas personas que en otras. Su nervio óptico se puede dañar aun cuando la presión interna del ojo esté en un nivel considerado normal. La presión puede aumentar si el líquido del interior de los ojos no se está drenando correctamente.

- Los ojos producen y drenan un líquido constantemente. Este líquido mantiene en su nivel correcto la presión de los ojos, para que conserven su forma correcta y así pueda usted ver.
- El líquido se drena de los ojos por un sistema de drenaje que va del iris a la córnea llamado “ángulo” y de ahí al exterior por unos conductos (como se muestra en la imagen de arriba). En las personas con glaucoma de ángulo abierto, el ángulo hacia los conductos está abierto, pero el líquido no se drena correctamente.
- Pueden haber varias razones por las que los ojos no drenen el líquido correctamente. Los conductos pueden ser demasiado estrechos o estar obstruidos.
- Si el líquido no drena al exterior, entonces se acumula dentro de los ojos. Esto puede aumentar la presión interna de los ojos. Si la presión llega a ser demasiado alta para sus ojos, se puede dañar su nervio óptico y así disminuir su capacidad para ver.

### ¿Cuáles son los factores de riesgo que pueden ocasionar glaucoma?

Las personas con mayor riesgo de desarrollar glaucoma son:

- Afroamericanos de más de 40 años de edad
- Personas de más de 60 años (especialmente de origen latino)
- Personas con antecedentes de glaucoma en la familia
- Personas con presión ocular elevada

### ¿Cómo determina el oftalmólogo que usted tiene glaucoma?

Su oftalmólogo puede hacer varias pruebas para saber si usted tiene glaucoma; por ejemplo:

- Medir la presión interna de los ojos
  - Usted puede tener glaucoma aun cuando la presión interna de sus ojos esté en un nivel considerado normal. Es por esa razón que el oftalmólogo hace otras pruebas para decidir si tiene glaucoma.
- Medir su visión lateral (llamada prueba del campo visual)
- Dilatar (ensanchar con gotas medicinales) las pupilas de los ojos, de modo que el oftalmólogo pueda observar el nervio óptico

Con el glaucoma, el nervio óptico se daña lentamente con el tiempo. El daño causado a los ojos puede no sentirse y la vista puede parecer normal. Por eso es importante que su oftalmólogo realice pruebas para detectar el glaucoma.

### ¿Qué tan común es el glaucoma de ángulo abierto?

- En Estados Unidos, tienen glaucoma de ángulo abierto entre 2 y 3 millones de personas (cerca de 1 por ciento de la población).
- El glaucoma es una causa importante de ceguera, tanto en Estados Unidos como en el resto del mundo.

## Conozca sus opciones

### ¿Cómo se trata el glaucoma de ángulo abierto?

Para tratar el glaucoma de ángulo abierto, los oftalmólogos reducen la presión interna de los ojos. No hay tratamientos para reparar los nervios ópticos dañados. Una vez que se pierde la vista, no hay manera de recuperarla.

Existen tres tipos de tratamientos para el glaucoma: medicamentos, cirugía con láser y cirugía convencional. Ninguno de estos tratamientos le curará el glaucoma, pero pueden ayudar a detener el daño a su nervio óptico.

| - Los medicamentos suelen ser el primer tratamiento para el glaucoma y funcionan en una de dos formas:; - Hacen que sus ojos produzcan menos líquido; - Aumentan la salida del líquido del interior de los ojos
| - La cirugía con láser actúa en una de dos formas:; - Ayuda a que sus ojos drenen mejor el líquido; - Disminuye la cantidad de líquido que producen sus ojos (este tipo de cirugía con láser no se explica en este resumen)
| - La cirugía convencional actúa en una de dos formas:; - Redirige el líquido para esquivar la parte del sistema de drenaje ocular que no funciona correctamente; - Crea nuevas vías para que el líquido drene de los ojos

### Medicamentos

Muchas personas con glaucoma se tratarán primero con medicamentos.

- Existen muchos tipos de medicamentos para tratar el glaucoma. Cada uno de estos tipos tiene varios nombres comerciales.
- La mayoría de los medicamentos son gotas que se aplican en los ojos (gotas oftálmicas) una o más veces al día.
- Algunos oftalmólogos pueden sugerir medicamentos para el glaucoma que se toman en pastillas, pero esto es mucho menos común, debido a sus efectos secundarios.

Es importante que use siempre su medicamento para el glaucoma, ya sea en gotas o en pastillas, exactamente como se lo haya ordenado el médico. Debe poner todo de su parte y no dejar de usar el medicamento ni un solo día. También es importante que siga acudiendo a sus exámenes periódicos con el oftalmólogo.

Medicamentos para disminuir la presión interna de los ojos

Tipo de medicamento | Nombre comercial | Cómo se usa | Cada cuánto se toma | ¿Existe en genérico? | Nombre del medicamento
Análogos de la prostaglandina | Lumigan^®^ | Gotas para los ojos | Una vez al día | No | Bimatoprost
Análogos de la prostaglandina | Travatan Z^®^ | Gotas para los ojos | Una vez al día | No | Travoprost
Análogos de la prostaglandina | Xalatan^®^ | Gotas para los ojos | Una vez al día | Sí | Latanoprost
Análogos de la prostaglandina | Zioptan^®^* | Gotas para los ojos | Una vez al día | No | Tafluprost^*^
Antagonistas beta-adrenérgicos | Betagan^®^ | Gotas para los ojos | Dos veces al día | Sí | Levobunolol
Antagonistas beta-adrenérgicos | Betoptic S^®^ | Gotas para los ojos | Dos veces al día | Sí | Betaxolol
Antagonistas beta-adrenérgicos | Ocupress^®^ | Gotas para los ojos | Dos veces al día | Sí | Carteolol
Antagonistas beta-adrenérgicos | Timoptic^®^ | Gotas para los ojos | Dos veces al día | Sí | Timolol
Inhibidores de la anhidrasa carbónica | Azopt^®^ | Gotas para los ojos | Tres veces al día | No | Brinzolamida
Inhibidores de la anhidrasa carbónica | Trusopt^®^ | Gotas para los ojos | Tres veces al día | Sí | Dorzolamida
Inhibidores de la anhidrasa carbónica | Diamox^®^ | Pastillas | Dos veces al día | Sí | Acetazolamida
Inhibidores de la anhidrasa carbónica | Neptazane^®^* | Pastillas | Dos veces al día | Sí | Metazolamida^*^
Agonistas alfa-adrenérgicos | Alphagan^®^ P | Gotas para los ojos | Tres veces al día | Sí | Brimonidina
Mióticos | Isopto^®^ Carpine^*^ | Gotas para los ojos | Hasta 4 veces al día | Sí | Pilocarpina^*^
Medicamentos en combinación | Combigan^®^ | Gotas para los ojos | Dos veces al día | No | Brimonidina y timolol
Medicamentos en combinación | Cosopt^®^ | Gotas para los ojos | Dos veces al día | Sí | Dorzolamida y timolol

* Estos medicamentos no se estudiaron en la investigación para este resumen.

#### ¿Qué dicen las investigaciones sobre los posibles beneficios de los medicamentos para el glaucoma?

- Todos los medicamentos para el glaucoma estudiados en este trabajo de investigación tienen la función de disminuir la presión de los ojos.
  - Los análogos de las prostaglandinas (Lumigan^®^, Travatan Z^®^, Xalatan^®^) y la combinación de los medicamentos dorzolamida y timolol (Cosopt^®^) al parecer pueden disminuir mejor la presión de los ojos que los otros medicamentos.
- Las personas que utilizan medicamentos para tratar el glaucoma tienen una menor probabilidad de sufrir daño al nervio óptico y de perder la visión lateral, que aquellas que no se tratan.

#### ¿Cuáles son los efectos secundarios posibles de los medicamentos para el glaucoma?

La Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA, por su sigla en inglés) de Estados Unidos lista los siguientes efectos secundarios posibles para los medicamentos de glaucoma.

- En general, los medicamentos en gotas oftálmicas para el glaucoma tienen estos efectos secundarios posibles:
  - Enrojecimiento de los ojos y su alrededor
  - Visión borrosa
  - Ardor y picazón
  - Comezón
  - Lagrimeo
  - Sensación de tener algo dentro del ojo
  - Sensibilidad a la luz
  - Ojos secos
  - Molestia en el ojo o el párpado
- Los análogos de las prostaglandinas (Lumigan^®^, Travatan Z^®^, Xalatan^®^, Zioptan^®^) pueden causar los efectos secundarios siguientes:
  - Oscurecimiento del iris (la parte con color del ojo que rodea la pupila)
  - Oscurecimiento del párpado
  - Cambios en las pestañas (mayor longitud, espesor, color o cantidad de las pestañas)
- Las pastillas de Diamox^®^ y Neptazane^®^ pueden causar los siguientes efectos secundarios:
  - Pérdida del apetito
  - Náusea y vómito
  - Diarrea
  - Sueño excesivo
  - Mal sabor en la boca
  - Hormigueo en las manos o pies
  - Anemia grave
  - Zumbido de oídos
  - Piedras (cálculos) en el riñón
  - Salpullido

La FDA advierte que los medicamentos para el glaucoma en pastillas pueden tener efectos secundarios graves o pueden causar reacciones alérgicas. Si usted está tomando dosis altas de aspirina o tiene enfermedad del hígado, los riñones, el corazón o los pulmones debe consultar a su oftalmólogo antes de tomar Diamox^®^ o Neptazane^®^.

Advertencias de la FDA respecto a Betagan^®^, Betoptic S^®^, Ocupress^®^, OptiPranolol^®^y Timoptic^®^:

- Las personas con problemas respiratorios tales como asma, bronquitis crónica o enfisema deben consultar a su oftalmólogo antes de usar alguno de estos medicamentos para tratar el glaucoma.
- Estos medicamentos pueden disminuir la presión arterial y el pulso, especialmente en las personas que toman medicamentos bloqueadores beta en pastillas, para tratar la presión arterial alta. Las personas que toman bloqueadores beta en pastillas para tratar la presión alta deben consultar a su oftalmólogo antes de usar uno de estos medicamentos para tratar el glaucoma.
- Las personas con diabetes insulinodependiente pueden no saber ni sentir cuando su azúcar en la sangre está baja mientras usan uno de estos medicamentos en gotas oftálmicas. Estas personas deben consultar a su oftalmólogo y al médico que trata su diabetes antes de usar uno de estos medicamentos para tratar el glaucoma.

#### ¿Qué dicen las investigaciones acerca de los posibles efectos secundarios de los medicamentos para el glaucoma?

- El enrojecimiento de los ojos es el efecto secundario más común de los medicamentos en gotas para tratar el glaucoma.
- Entre las análogos de las prostaglandinas, el latanoprost (Xalatan^®^) parece causar menos enrojecimiento de los ojos que el bimatoprost (Lumigan^®^) o el travoprost (Travatan Z^®^).
- El timolol (Timoptic^®^) parece causar menos enrojecimiento de los ojos que los análogos de las prostaglandinas. Sin embargo, el timolol (Timoptic^®^) tiende más a causar efectos secundarios, como falta de aire y frecuencia cardiaca lenta.

### Cirugía con láser

Otra opción para tratar el glaucoma es la cirugía con láser. Los oftalmólogos pueden utilizar un rayo de luz concentrada —o sea un rayo láser— para ayudar a los ojos a drenar mejor.

La cirugía con láser se puede hacer en un centro de cirugía ambulatoria y no requiere permanecer en un hospital. Lo usual es que cada ojo se opere en una visita distinta, con una diferencia de varios días o semanas. Toda la operación puede completarse en un lapso de minutos. Se aplican gotas en los ojos para adormecerlos y que usted no sienta dolor. La persona se sienta en una silla durante la operación, y el oftalmólogo usa un microscopio y un lente especiales para dirigir el rayo láser hacia el ojo.

#### ¿Qué dice la investigación sobre los posibles beneficios de la cirugía con láser?

- Los investigadores encontraron que la cirugía con láser es eficaz para disminuir la presión del ojo en las personas con glaucoma.
- La cirugía con láser puede disminuir la necesidad de usar medicamentos para el glaucoma, pero no existe suficiente investigación para saberlo con certeza. Es posible que algunas personas tratadas con láser deban seguir usando medicamentos para tratar el glaucoma.
- Las personas que se someten a la cirugía con láser para tratar el glaucoma tienen una menor probabilidad de sufrir daño al nervio óptico o pérdida de la visión lateral que aquellas que no se tratan.

#### ¿Cuáles son los posibles efectos secundarios de la cirugía con láser?

- Reacciones temporales de enrojecimiento en los ojos, visión borrosa, aumento de la presión ocular e hinchazón de los ojos (suelen desaparecer en un plazo de 24 horas)

Nota: La cirugía con láser no cura el glaucoma. Algunas personas tratadas con láser aún pueden necesitar medicamentos para tratar el glaucoma. Los efectos de la cirugía con láser pueden desaparecer después de varios años y su oftalmólogo puede sugerir una nueva operación con láser u otro tratamiento. Después de la cirugía con láser, es importante que siga acudiendo a sus exámenes periódicos con el oftalmólogo.

### Cirugía convencional

La cirugía convencional es una tercera opción para tratar el glaucoma.

La cirugía convencional para el glaucoma puede consistir en:

- Redirigir el líquido y desviarlo de la parte del sistema de drenaje ocular que no funciona correctamente
- Crear nuevas vías de drenaje para el líquido en los ojos
  - A veces, esto se logra colocando dentro de los ojos dispositivos pequeños, tales como tubos.

Estas cirugías se hacen en una sala de operaciones. Lo usual es que cada ojo se opere en una visita distinta, unas 4 a 6 semanas de por medio. Antes de la operación, se administran medicamentos para adormecer el ojo y que usted no sienta dolor. También se le administran medicamentos para ayudarle a relajarse.

Nota: La cirugía convencional no cura el glaucoma. Algunas personas tratadas con cirugía convencional aún pueden necesitar medicamentos para tratar el glaucoma. Los efectos de la cirugía pueden desaparecer después de unos años y su oftalmólogo puede sugerir una nueva operación u otro tratamiento. Después de la operación, es importante que siga acudiendo a sus exámenes periódicos con el oftalmólogo.

#### ¿Qué dice la investigación sobre los posibles beneficios de la cirugía convencional?

- Los investigadores encontraron que un tipo de cirugía para crear nuevas vías de drenaje, llamada “trabeculectomía” es eficaz para disminuir la presión del ojo.
- Las personas sometidas a trabeculectomía para tratar el glaucoma tienen una menor probabilidad de sufrir daño al nervio óptico y perder la visión lateral que aquellas que no se tratan.
- No existen suficientes investigaciones que comparen todos los tipos de cirugía convencional para saber con seguridad cuál resulta más eficaz.
- Se necesitan más investigaciones para saber si la cirugía convencional funciona bien o no, comparada con los medicamentos o cirugía con láser, para conservar la visión lateral o disminuir el daño al nervio óptico a largo plazo.

#### ¿Cuáles son los posibles efectos secundarios y riesgos de la cirugía convencional?

- Todas las cirugías de glaucoma conllevan cierto riesgo de sangrado, infección y pérdida de la vista, aunque son raros.
- Algunas cirugías aumentan el riesgo de desarrollar cataratas.

### Comparación de los tratamientos del glaucoma

| Medicamentos | Cirugía con láser | Cirugía convencional
Descripción | Gotas oftálmicas o pastillas que se administran una o más veces al día | Cirugía con láser que se hace en un centro de cirugía ambulatoria y dura solamente unos minutos; - Los efectos de esta operación pueden desaparecer después de unos años. | Cirugía que se hace en una sala de operaciones.; - Los efectos de esta operación pueden desaparecer después de unos años.
Posibles beneficios | - Reduce la presión interna del ojo; - Los análogos de las prostaglandinas (Lumigan^®^, Travatan Z^®^, Xalatan^®^) y una combinación de los medicamentos dorzolamida y timolol (Cosopt^®^) parecen disminuir la presión de los ojos mejor que los otros medicamentos.; - Ayuda a evitar daño al nervio óptico y pérdida de la visión lateral | - Reduce la presión interna del ojo; - Ayuda a evitar daño al nervio óptico y pérdida de la visión lateral; - Puede disminuir la necesidad de medicamentos para tratar el glaucoma, pero no existe suficiente investigación para saberlo con certeza; - Algunas personas tratadas usando cirugía con láser pueden necesitar aún medicamentos para tratar el glaucoma. | - La trabeculectomía reduce la presión interna del ojo; - La trabeculectomía ayuda a evitar daño al nervio óptico y pérdida de la visión lateral; - Algunas personas tratadas con cirugía convencional pueden necesitar aún medicamentos para tratar el glaucoma.
Posibles efectos secundarios | - Las gotas oftálmicas pueden causar enrojecimiento, visión borrosa, picazón y comezón en el ojo; - Las pastillas pueden causar náusea, vómito, diarrea y sueño.; - Las pastillas pueden causar efectos secundarios o reacciones alérgicas más graves que las gotas oftálmicas. | - Enrojecimiento temporal del ojo, visión borrosa, aumento de la presión ocular e hinchazón de los ojos (suelen desaparecer todas en las 24 horas siguientes a la operación) | - Mayor riesgo de sangrado, infección y pérdida de la vista, aunque son raros; - Mayor riesgo de desarrollar cataratas

## Tome una decisión

### ¿En qué cosas debo pensar?

Se deben considerar muchas cosas al decidir la mejor forma de tratar el glaucoma. El tratamiento que proponga su oftalmólogo dependerá de:

- Cuánto daño, si lo hay, ha sufrido ya su nervio óptico
- Sus otras condiciones médicas

Al decidir cómo tratar el glaucoma, usted debe considerar:

- Los beneficios y los efectos secundarios posibles de cada opción de tratamiento
- Qué piensa usted de los medicamentos, la cirugía con láser o la cirugía convencional

### ¿Cuánto cuesta el tratamiento?

El costo para usted del tratamiento del glaucoma depende de:

- Su seguro médico
- El tipo de cirugía que se haga
- Si el medicamento existe en forma genérica (los medicamentos genéricos cuestan menos que los de marca comercial)

### Precios de mayoreo de los medicamentos para el glaucoma

Los precios de mayoreo de los medicamentos para el glaucoma se indican a continuación. Los precios de mayoreo son los precios que pagan las farmacias. Los precios se dan aquí para que pueda usted comparar el costo de los distintos medicamentos, de modo que sepa cuáles son más y menos caros. El costo que cada medicamento tenga para usted dependerá de su seguro médico y si existe en forma genérica.

Nombre comercial | Concentración | Cada cuánto se toma | Precio del de marca por mes^*^ | Nombre del medicamento | Precio del genérico por mes^*^
Análogos de la prostaglandina
Lumigan^®^ | 0.01% | Una vez al día | $115 | Bimatoprost | NG
Lumigan^®^ | 0.03% | Una vez al día | $115 | Bimatoprost | NG
Travatan Z^®^ | 0.004% | Una vez al día | $115 | Travoprost | NG
Xalatan^®^ | 0.005% | Una vez al día | $120 | Latanoprost | $90
Zioptan^®^ | 0.0015% | Una vez al día | $115 | Tafluprost | NG
Antagonistas beta-adrenérgicos
Betagan^®^ | 0.25% | Dos veces al día | $25 | Levobunolol | $15
Betagan^®^ | 0.5% | Dos veces al día | $40 | Levobunolol | $20
Betoptic S^®^ | 0.25% | Dos veces al día | $185 | Betaxolol | ND
Betoptic S^®^ | 0.5% | Dos veces al día | ND | Betaxolol | $125
Ocupress^®^ | 1% | Dos veces al día | ND | Carteolol | $20
Timoptic^®^ | 0.25% | Dos veces al día | $125 | Timolol | $15
Timoptic^®^ | 0.5% | Dos veces al día | $135 | Timolol | $20
Inhibidores de la anhidrasa carbónica
Azopt^®^ | 1% | Tres veces al día | $135 | Brinzolamida | NG
Trusopt^®^ | 2% | Tres veces al día | $85 | Dorzolamida | $70
Diamox^®^ | 250 mg | Dos veces al día | ND | Acetazolamida | $266
Diamox^®^ | 500 mg (liberación prolongada) | Dos veces al día | $390 | Acetazolamida | $260
Neptazane^®^ | 50 mg | Dos veces al día | $210 | Metazolamida | $180
Neptazane^®^ | 50 mg | Tres veces al día | $315 | Metazolamida | $270
Agonistas alfa-adrenérgicos
Alphagan^®^ P | 0.1% | Tres veces al día | $180 | Brimonidina | ND
Alphagan^®^ P | 0.15% | Tres veces al día | $200 | Brimonidina | $180
Mióticos
Isopto^®^ Carpine | 1% | Hasta 4 veces al día | $85 | Pilocarpina | $70
Isopto^®^ Carpine | 2% | Hasta 4 veces al día | $85 | Pilocarpina | $75
Isopto^®^ Carpine | 4% | Hasta 4 veces al día | $90 | Pilocarpina | $80
Medicamentos combinados
Combigan^®^ | 0.2–0.5% | Dos veces al día | $105 | Brimonidina y timolol | NG
Cosopt^®^ | 0.2–0.5% | Dos veces al día | $80 | Dorzolamida y timolol | $60

* Los precios son los precios promedio de mayoreo según el RED BOOK Online^®^ redondeados a los $5 más cercanos. Los precios del medicamento genérico son el valor medio de los precios publicados de los distintos fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = Precio no disponible; NG = No existe forma genérica

### Pregunte a su oftalmólogo (médico de la vista)

- ¿Mi glaucoma se puede tratar con medicamentos, o piensa usted que necesitaré cirugía con láser o cirugía convencional?
- ¿Qué pasa si también tengo cataratas o las desarrollo después?
- ¿Qué medicamento es el mejor para mí?
- ¿Cómo sabremos si el medicamento no está funcionando?
- ¿Qué ocurre si dejo pasar una dosis del medicamento? ¿Hay formas de ayudarme a recordar que debo tomarlo?
- ¿Podría mi medicamento para el glaucoma interactuar con otros medicamentos que estoy tomando?
- Si necesito cirugía con láser o cirugía convencional, ¿cuánto tiempo estaré ausente del trabajo o de otras actividades?
- Si me tratan con cirugía, ¿aún necesitaré medicamentos? ¿La cirugía se hace una sola vez o necesitaré otra operación en el futuro?
- ¿A qué efectos secundarios graves debo estar atento y cuándo debo consultarlo al respecto?
- ¿Con qué frecuencia me deben examinar los ojos para saber si el tratamiento está funcionando?

Otras preguntas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

Anote aquí las respuestas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

## Fuente

La información de este resumen proviene del informe Treatment for Glaucoma: Comparative Effectiveness (Tratamiento del glaucoma: eficacia comparada), de abril de 2012. El informe fue producido por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Johns Hopkins) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Estas páginas incluyen más información sobre el glaucoma: www.nei.nih.gov/health/espanol/glaucoma/glaucoma_paciente.asp y www.nei.nih.gov/health/espanol/glaucoma/index.asp.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con glaucoma de ángulo abierto.

Esta guía fue traducida de la publicación en inglés titulada Treatments for Open-Angle Glaucoma: A Review of the Research for Adults.