# Diabetes gestacional

Guía para la mujer embarazada

La diabetes gestacional es un tipo de diabetes que puede ocurrir durante el embarazo. Significa que usted nunca ha tenido diabetes antes. Tener diabetes gestacional significa que usted tiene un problema de azúcar alta en la sangre durante el embarazo. El tratamiento consiste en controlar el azúcar en la sangre. Ese control ayuda a evitar un parto difícil. Ayuda también a mantener a su bebé saludable.

## Hechos resumidos

- La diabetes gestacional es un tipo de diabetes que puede ocurrir durante el embarazo. Por lo general desaparece después del parto.
- La diabetes gestacional se trata controlando el azúcar en la sangre. Algunas mujeres logran controlarla siguiendo una dieta especial para diabetes y manteniéndose activas. Otras necesitan inyectarse insulina o tomar pastillas contra la diabetes.
- La insulina y dos tipos de pastillas contra la diabetes pueden bajar el azúcar en la sangre en las mujeres con diabetes gestacional.
- Muchas mujeres que tienen diabetes gestacional tendrán diabetes tipo 2 más adelante en la vida. El control del aumento de peso durante el embarazo puede evitar que ocurra la diabetes tipo 2 más adelante.
- Es importante seguir haciéndose regularmente la prueba de diabetes tipo 2 después del embarazo.

## ¿Qué cubre esta guía?

Esta guía le ayudará a hablar con su médico o partera sobre la diabetes gestacional. Le ayuda a responder las siguientes preguntas:

- ¿ Qué es la diabetes gestacional?
- ¿ Cómo se trata?
- ¿ Cómo hay que cuidarse después del embarazo?

Esta guía se basa en una revisión, financiada por el gobierno, de la investigación sobre la diabetes gestacional.

## ¿Qué no cubre esta guía?

Esta guía no incluye el tratamiento de la diabetes tipo 1 ó 2 durante el embarazo. Las diabetes tipo 1 y 2 son diferentes de la diabetes gestacional.

## Aprenda sobre la diabetes gestacional

### ¿Qué es la diabetes?

La diabetes ocurre cuando el cuerpo tiene un problema con la insulina. La insulina es una hormona. Ayuda al organismo a convertir el azúcar de la sangre en energía.

Cuando usted tiene diabetes, el cuerpo no elabora la insulina suficiente o no la aprovecha como debería. Entonces se acumula glucosa (azúcar) en la sangre porque el organismo no puede utilizar el azúcar sin ayuda de la insulina. Esto causa que el azúcar en la sangre se mantenga elevada.

Existen diferentes tipos de diabetes:

- Diabetes tipo 1: la mayoría de los casos se diagnostican durante la niñez o la adolescencia. El tratamiento consiste siempre en la inyección de insulina.
- Diabetes tipo 2: por lo general se diagnostica durante la edad adulta. En algunos casos se trata simplemente con dieta. Pueden necesitarse también pastillas para la diabetes o insulina.
- Diabetes gestacional: es un tipo de diabetes que ocurre durante el embarazo. Por lo general desaparece después del parto.

### ¿Qué es la diabetes gestacional?

En la diabetes gestacional, el cuerpo tiene un problema con la insulina durante el embarazo. Cuando una mujer está embarazada, su cuerpo necesita más insulina para mantener el azúcar de la sangre en el nivel correcto. El cuerpo de la mujer produce más insulina durante el embarazo. Cuando esa insulina adicional no es suficiente para mantener el azúcar de la sangre en un nivel normal, el azúcar en la sangre se eleva. Eso es lo que llamamos diabetes gestacional. Por lo general, el azúcar en la sangre vuelve a su nivel normal después del parto.

### ¿Quién puede padecer de diabetes gestacional?

Cerca de 7 de cada 100 mujeres embarazadas padecen de diabetes gestacional.

La diabetes gestacional es más frecuente en:

- Mujeres con sobrepeso.
- Mujeres con familiares que han tenido diabetes gestacional.
- Mujeres con familiares que tienen diabetes tipo 2.
- Mujeres estadounidenses de ascendencia africana, indígena e hispana/latina.

### ¿Cómo sé si tengo diabetes gestacional?

La diabetes gestacional comienza durante el segundo trimestre. Por lo general, los médicos y parteras hacen la prueba para detectarla en el quinto o sexto mes del embarazo. La prueba consiste en darle a tomar a la mujer una bebida azucarada especial y hacerle después el examen de azúcar en la sangre.

## ¿Por qué debe tratarse la diabetes gestacional?

El tener el azúcar alta en la sangre puede hacer que el bebé crezca demasiado; es decir 9 libras o más. Éste es el problema más frecuente en la diabetes gestacional. Se conoce como macrosomía. Un bebé demasiado grande puede causar complicaciones en el parto. Al nacer, el bebé también puede tener problemas para respirar o tener el azúcar en la sangre demasiado baja.

Las mujeres con diabetes gestacional pueden dar a luz bebés sanos. Mantener controlada el azúcar en la sangre puede ayudar a evitar problemas.

## Opciones para el parto

Si usted tiene diabetes gestacional, su médico o partera pueden conversar con usted sobre distintas opciones de parto. La finalidad es lograr un parto seguro y un bebé sano.

Cuando la mujer tiene diabetes gestacional, es común que el médico o partera induzcan (provoquen) el parto antes del término del embarazo. Esto se hace a veces para que el bebé no crezca tanto. La investigación no ha aclarado qué es mejor para la madre y el bebé, si adelantar el parto o esperar a que ocurra espontáneamente.

A veces los médicos o las parteras proponen hacer una operación cesárea. Es otra opción para evitar los problemas del parto de un bebé grande. La cesárea es una operación que se hace para que el bebé nazca por el abdomen de la madre. La investigación tampoco ha aclarado si la cesárea es mejor, para la mamá y el bebé, que inducir el parto o esperar a que ocurra espontáneamente.

## ¿Cómo puedo tratar la diabetes gestacional?

### Comiendo sanamente y manteniéndose activa

Una dieta sana y mantenerse activa son dos de las medidas más importantes para controlar el azúcar en la sangre y tratar la diabetes gestacional. Actividades como caminar y nadar son muy útiles. La actividad no tiene que ser difícil. La idea es levantarse y ponerse en movimiento. Hable con su médico o partera para preparar un plan de ejercicio que a usted le funcione.

Todas las mujeres con diabetes gestacional necesitan seguir un plan de alimentación especial para diabetes. Su médico o partera pueden pedirle que visite a un dietista o educador en diabetes. El dietista o educador en diabetes le ayudará a crear un plan apropiado para usted.

El plan de alimentación para la diabetes se basa en reglas sencillas, como:

- Cuidar el tamaño de las porciones.
- Comer alimentos variados, como frutas frescas, verduras y cereales de grano entero.
- Limitar las calorías de grasas a 30 por ciento o menos cada día.

Para controlar la diabetes gestacional es muy importante también cuidar el aumento de peso durante el embarazo. Pregunte a su médico o partera cuál sería el aumento de peso correcto para usted.

Para aprender más sobre el plan de alimentación para la diabetes, visite la página web de la National Diabetes Information Clearinghouse (Centro Coordinador Nacional de Información sobre la Diabetes): www.diabetes.niddk.nih.gov/index_sp.htm.

### Medicamentos

La mayoría de las mujeres pueden controlarse la diabetes gestacional siguiendo un plan de alimentación para diabetes y siendo más activas. Otras necesitarán también insulina o pastillas contra la diabetes para controlar su azúcar en la sangre. Para tratar la diabetes gestacional se usan la insulina y dos tipos de pastillas contra la diabetes. Todos estos medicamentos tienen el efecto de disminuir el azúcar en la sangre. Hasta ahora, la investigación indica que pueden usarse sin riesgo durante el embarazo.

#### Insulina

La insulina necesita inyectarse (con una pequeña jeringa). La insulina que se inyecta es como la que produce el cuerpo, excepto que se hace en un laboratorio. Hay muchos tipos de insulina.

#### Pastillas contra la diabetes

Se han utilizado dos tipos de pastillas para tratar la diabetes gestacional. La gliburida (Diabeta®, Glynase PresTab®, Micronase®) es una pastilla que ayuda a aumentar la cantidad de insulina en el cuerpo. La metformina (Glucophage®) bloquea la elaboración de glucosa (azúcar) en el hígado.

Los dos tipos de pastillas que se usan para tratar la diabetes gestacional se usan también en la diabetes tipo 2. Si su médico le receta pastillas para la diabetes gestacional, tal vez quiera conocer también otra guía. Se llama Pastillas para la diabetes tipo 2: Guía para adultos (2007), y puede obtenerse en esta página web: www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

## Aprenda sobre el azúcar en la sangre

### ¿Cómo se mide el azúcar en la sangre?

Puede medirla en su casa, mediante un leve pinchazo en un dedo. Para esta prueba se usa un medidor de glucosa que indica el nivel de azúcar en la sangre. Su médico o partera puede enseñarle a usar el medidor. Probablemente le pidan medirse el azúcar a diferentes horas del día.

El diagrama siguiente indica los valores normales de azúcar en la sangre en diferentes horas del día. Pregunte a su médico o partera cuáles son los valores ideales para usted.

Hora en que se mide el azúcar en la sangre | Valor ideal del azúcar en la sangre
Antes de comer | Menos de 95
Una hora después de comer | Menos de 130
Dos horas después de comer | Menos de 120

Es importante que anote los valores de sus pruebas de azúcar en la sangre. Los resultados le ayudarán al médico o partera a decidir en su próxima cita si debe usted empezar a usar medicamentos para controlar el azúcar en la sangre. Si ya está usted usando insulina o pastillas, los resultados le ayudarán a decidir si deben hacerse ajustes a su medicamento.

### Cuide que su azúcar en la sangre no baje demasiado

Una disminución excesiva del azúcar en la sangre es lo que se llama hipoglucemia. Puede causarle mareos, sudoración, confusión, temblores, hambre y debilidad.

Tanto la insulina como las pastillas para la diabetes gestacional pueden hacer que el azúcar baje demasiado.

La disminución excesiva del azúcar es más común en las mujeres que usan insulina que en las que toman metformina (Glucophage®).

Advertencia:

Si cree que su azúcar está baja, coma o beba inmediatamente algo con azúcar. Su médico o partera pueden sugerirle opciones como caramelos, jugos o tabletas de glucosa.

## Cómo cuidarse de la diabetes tipo 2 después del parto

La diabetes gestacional suele desaparecer después de dar a luz. El azúcar en la sangre vuelve a la normalidad después del parto. Tal vez pueda dejar de medirse en casa el azúcar por medio del pinchazo. Sin embargo, debe tener presentes algunos aspectos importantes.

Las mujeres que han tenido diabetes gestacional están propensas a tener diabetes tipo 2 más adelante. Tienen más probabilidad que las mujeres que no han tenido diabetes gestacional. La probabilidad de tener diabetes tipo 2 más adelante es mayor también en las mujeres que suben de peso más de lo normal durante el embarazo.

Hay medidas que ayudan a reducir el riesgo de tener diabetes más adelante. Es útil mantener el peso saludable, llevar una dieta sana y mantenerse activa. Estas simples medidas son importantes durante el embarazo y después.

No olvide decirles a todos sus médicos y enfermeras que tuvo diabetes gestacional durante su embarazo. Es muy importante que de vez en cuando le midan el azúcar en la sangre en el consultorio o clínica. La prueba le permitirá cerciorarse de que no ha desarrollado diabetes tipo 2. Su médico o enfermera podrá indicarle cada cuánto debe hacerse la prueba de azúcar en la sangre.

Aproximadamente 60 de cada 100 mujeres que tienen diabetes gestacional tendrán diabetes tipo 2 unos 10 años después del embarazo. La buena noticia es que usted puede reducir ese riesgo. Mantenga un peso adecuado, lleve una dieta sana, manténgase activa y mida su azúcar regularmente.

## Preguntas que puede tener

### ¿Puedo controlar mi diabetes gestacional comiendo sanamente y manteniéndome activa?

Sí, la mayoría de las mujeres con diabetes gestacional pueden controlar su azúcar en la sangre con el plan de alimentación para la diabetes y ejercicio. También es importante cuidar el aumento de peso durante el embarazo. Busque con su médico o partera un plan que le funcione.

### Si necesito medicamentos, ¿puedo tomar una pastilla o tengo que inyectarme?

Muchas mujeres pueden controlar su azúcar simplemente tomando una pastilla. Otras mujeres necesitan comenzar a tratarse con insulina. Pregunte a su médico o partera cuál es el plan de tratamiento para usted.

### ¿Cada cuánto necesito medirme el azúcar en la sangre?

Algunas mujeres necesitan medirse el azúcar en la sangre varias veces al día. Esto por lo general se hace por la mañana antes del desayuno y después de cada comida. Su médico o partera podrá decirle a qué horas debe usted medirse.

### Después del parto, ¿cuánto tiempo se deja pasar para hacerse la prueba de la diabetes tipo 2? ¿Cada cuánto tiempo necesito hacerme la prueba?

La investigación no indica exactamente cuándo y con qué frecuencia necesita hacerse la prueba. Lo importante es que se haga la prueba regularmente. El tener diabetes gestacional significa que usted tiene un mayor riesgo de padecer de diabetes tipo 2 más adelante.

## ¿Dónde puedo obtener más información?

Si desea obtener una copia electrónica de esta guía u otro material para conocer tratamientos y medicamentos para otras enfermedades, visite esta página web: www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Si desea un ejemplar impreso gratuito, llame a:

AHRQ Publications Clearinghouse (800) 358–9295

Pida la Publicación de AHRQ Número 09(10)-EHC014-B.

Si desea más información sobre la diabetes gestacional, visite la página web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/diabetesandpregnancy.html.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 45 informes de investigación. La revisión se titula Therapeutic Management, Delivery, and Postpartum Risk Assessment and Screening in Gestational Diabetes (Control terapéutico, parto, evaluación de riesgos de posparto y detección en la diabetes gestacional) (2008) y fue escrita por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia Johns Hopkins University). La revisión se actualizó en la revista especializada Obstetrics & Gynecology (Obstetricia y Ginecología) de 2009.

## Related Content

Research Review

Clinician Guide

Consumer Guide