# Opciones de tratamiento para la ERGE o enfermedad por reflujo del ácido estomacal

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Un médico le dijo que tiene la enfermedad por reflujo gastroesofágico (ERGE), una enfermedad crónica que causa dolor y ardor constantes en el pecho y la garganta (acidez estomacal). La ERGE se conoce también como “enfermedad por reflujo de ácido” y puede también llamársele GERD, por su sigla en inglés.
- Usted quiere saber qué dicen las investigaciones acerca de sus opciones.

### No es apropiada si

- A veces tiene acidez estomacal o reflujo de ácido, pero un médico no le ha dicho que sea ERGE.
- Tiene menos de 18 años de edad. Esta información proviene de investigación realizada en adultos.

Es común tener acidez estomacal ocasionalmente. Tener acidez estomacal no necesariamente significa tener ERGE. La ERGE es una forma más seria de reflujo de ácido, con síntomas graves que ocurren frecuentemente y por un largo período de tiempo. Su médico puede confirmarle si tiene ERGE.

### ¿Qué cubre este resumen?

- En este resumen se describe la ERGE y se explican las investigaciones sobre los tipos de tratamiento. También ofrece los resultados de las investigaciones sobre los beneficios y riesgos de cada tratamiento. El resumen también puede ayudarle a hablar con su médico sobre la ERGE.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés), organismo de investigación del gobierno federal, revisaron 166 estudios de investigación sobre la ERGE. Este informe lo revisaron clínicos, investigadores y el público en general. El informe puede leerse en www.effectivehealthcare.ahrq.gov/gerdupdate.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la enfermedad por reflujo gastroesofágico?

La ERGE (o también GERD, por su sigla en inglés) es una condición persistente en la cual el contenido del estómago regresa al esófago (el “tubo” que lleva el alimento de la boca al estómago). Los médicos llaman a esto “reflujo de ácido”.

Hay varias razones que hacen que las personas padezcan de ERGE. Una posible razón tiene que ver con el músculo que está en la base del esófago. Normalmente, este músculo se cierra para evitar que el alimento y el ácido del estómago regresen o suban al esófago. En algunas personas con ERGE, este músculo no siempre funciona correctamente.

- La ERGE suele causar acidez estomacal, una sensación de ardor en el pecho y la garganta. La acidez estomacal puede ocurrir muchas veces a la semana, sobre todo después de comer o en la noche.
- La ERGE puede también causarle tos o que tenga síntomas de asma. Puede también darle a su voz un tono ronco y rasposo. Estos síntomas pueden presentarse aunque usted no tenga acidez estomacal. El ácido también puede dejarle un sabor agrio en la boca.

### ¿Qué tan común es la ERGE?

- La ERGE es uno de los problemas de salud más comunes en los adultos.

### ¿Qué más debo saber sobre la ERGE?

- La acidez estomacal puede seguir repitiéndose si no se trata.
- Si no se trata la ERGE, ésta puede causar problemas de salud graves. El ácido puede dañar el esófago y hacer dificultoso el tragar.
- En algunas personas con ERGE, las células del esófago pueden volverse anormales. Estas células anormales podrían originar cáncer del esófago, aunque esto es raro.

## Conozca sus opciones

### ¿Cómo se trata la ERGE?

Tal vez necesite hacer cambios en su estilo de vida, como mantener un peso sano, dejar de fumar, tomar menos bebidas alcohólicas o evitar los alimentos que empeoran la ERGE.

Las opciones para tratar la ERGE pueden variar según la persona.

#### Medicamentos

La mayoría de las personas eligen tomar medicamentos para la ERGE como su primera opción.

#### Cirugía

En algunas personas, la cirugía puede aliviar los síntomas de la ERGE y disminuir la cantidad de medicamentos que se necesitan.

#### Tratamientos endoscópicos

Los tratamientos endoscópicos para la ERGE son más nuevos y aún se están estudiando, así que se sabe menos de su eficacia y seguridad.

En las páginas siguientes, encontrará más información sobre estos tipos de tratamiento.

### Medicamentos

Diferentes medicamentos pueden ayudar a controlar los problemas causados por la ERGE.

- Algunos alivian los síntomas de acidez estomacal cuando ocurre, mientras que otros ayudan a evitar la acidez estomacal u otros problemas.
- Algunos medicamentos se toman solamente cuando es necesario y otros se toman diariamente por un par de semanas o meses. Otros deben tomarse todos los días y por años.
- Algunos medicamentos pueden comprarse sin receta, mientras que con otros se necesita una receta. Otros pueden conseguirse tanto con receta como sin receta.
- Los tres tipos principales de medicamentos para tratar la ERGE son los antiácidos, los antagonistas del receptor de histamina tipo 2 (H2RA, por su sigla en inglés) y los inhibidores de la bomba de protones (PPI, por su sigla en inglés).

#### Antiácidos

- Los antiácidos detienen la acidez estomacal neutralizando (debilitando) el ácido del estómago.
- Actúan rápidamente para tratar los síntomas leves de la ERGE.
- Los antiácidos tienen muchos nombres; como Mylanta^®^, Rolaids^®^ o Tums^®^ y pueden adquirirse sin receta.
- Se toman en forma de pastillas o líquido.
- Tal vez deba seguir tomando antiácidos junto con un H2RA o un PPI, para controlar los síntomas.
- Los H2RA y los PPI tienen un efecto prolongado comparado con los antiácidos de acción rápida, pero no empiezan a actuar con la misma rápidez.

#### Antagonistas del receptor de histamina tipo 2 (H2RA)

- Los H2RA hacen que su estómago produzca menos ácido. Cuando su estómago tiene menos ácido es menos probable que tenga acidez estomacal.
- Todos los H2RA están disponibles con o sin receta.
- Se toman en forma de pastillas.

Nombre de los H2RA

Nombre genérico | Nombre comercial
Famotidina | Pepcid AC^®^; Calmicid^®^; Fluxid^®^; Mylanta AR^®^
Nizatidina | Axid^®^; Axid AR^®^
Ranitidina | Zantac^®^; Tritec^®^; Wal-Zan^®^
Cimetidina | Tagamet^®^

#### Inhibidores de la bomba de protones (PPI)

- Los PPI hacen que el estómago produzca menos ácido, lo que ayuda a evitar la acidez estomacal.
- Muchos PPI se venden solamente con receta, pero algunos están disponibles sin receta.
- Se toman en forma de pastillas.

Nombre de los PPI

Nombre genérico | Nombre comercial
Omeprazol | Prilosec^®^*, Losec^®^*, Omesec^®^*
Omeprazol con bicarbonato de sodio | Zegerid^®^*
Lansoprazol | Prevacid^®^*
Pantoprazol | Protonix^®^
Rabeprazol | Aciphex^®^
Esomeprazol | Nexium^®^
Dexlansoprazol | Dexilant^®^

* Disponible sin receta médica.

#### ¿Qué dicen las investigaciones sobre los medicamentos para la ERGE?

- Los PPI funcionan mejor que los H2RA para aliviar la acidez estomacal y ayudar a que el esófago se cure.
- La mayoría de los PPI funcionan igualmente bien para evitar la acidez estomacal.
- Las presentaciones con y sin receta de los PPI parecen funcionar igual de bien para evitar la acidez estomacal y ayudar a que el esófago se cure.
- En algunos casos, una dosis (cantidad) pequeña de PPI puede funcionar tan bien como una dosis más grande.
- Tomar un PPI todos los días parece funcionar mejor que tomarlo solamente cuando hay síntomas.
- Los PPI pueden disminuir la tos, pero no la ronquera causada por la ERGE, aunque no existe suficiente investigación para poder afirmarlo con certeza.
- No existe suficiente investigación para saber si los PPI reducen el asma causada por la ERGE.
- Los pacientes con mucho sobrepeso no responden tan bien a los medicamentos.

#### ¿Qué efectos secundarios pueden causar?

- Los antiácidos pueden causar efectos secundarios, tales como diarrea o estreñimiento.
- Los posibles efectos secundarios de los H2RA son dolor de cabeza, estreñimiento, diarrea, náusea o vómito.
- Los PPI pueden causar efectos secundarios, tales como diarrea, náusea, vómito, dolor abdominal (de barriga), malestar estomacal y dolor de cabeza.
- Los PPI pueden aumentar la posibilidad de adquirir una infección intestinal (diarrea) o pulmonar (neumonía). Pueden también aumentar la posibilidad de fracturarse un hueso. Sin embargo, estos efectos secundarios son menos frecuentes.

La Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos advirtió en 2009 que tomar el PPI omeprazol (nombre comercial Prilosec^®^) al mismo tiempo que el clopidogrel (nombre comercial Plavix^®^) disminuye la eficacia del clopidogrel. El clopidogrel es un medicamento que previene ataques al corazón y derrames. Funciona evitando que la sangre forme coágulos en las arterias del corazón o los vasos sanguíneos del cerebro. Estos coágulos de sangre pueden ocasionar un ataque al corazón o un derrame.

### Cirugía

En algunas personas, la cirugía para fortalecer la barrera entre el estómago y el esófago puede ser una opción de tratamiento para el reflujo de ácido. Esta cirugía para tratar la ERGE se llama “fundoplicatura”. Su médico puede decirle si la cirugía puede ayudarle.

#### ¿Cómo funciona la cirugía para la ERGE?

- En la fundoplicatura, la parte superior del estómago se envuelve alrededor de la base del esófago y ahí se sujeta.
- Esto ayuda a fortalecer el músculo de la base del esófago que se cierra para evitar que el alimento y el ácido regresen o suban.
- Es posible que el cirujano pueda operar utilizando un instrumento llamado “laparoscopio”. El laparoscopio es un tubo delgado con una cámara minúscula que el cirujano introduce en el abdomen a través de cortes pequeños, además de otros instrumentos diminutos, para hacer la cirugía.
- Por lo general, la recuperación posterior a la cirugía con laparoscopio es más rápida que cuando el cirujano tiene que hacer un corte grande en el abdomen para operar.

Hay dos tipos de cirugía: la fundoplicatura total y la fundoplicatura parcial

#### ¿Qué dicen las investigaciones acerca de la cirugía?

- La cirugía de fundoplicatura funciona igualmente bien como los medicamentos solos para evitar que ocurra reflujo ácido y acidez estomacal. Sin embargo, después de la cirugía aún puede necesitar medicamentos para controlar los síntomas.
- La cirugía puede hacerse de varias maneras (por ejemplo, con laparoscopio o a través de un corte grande en el abdomen), pero todas funcionan prácticamente igual.

#### ¿Qué efectos secundarios puede causar?

- La cirugía de fundoplicatura puede hacer que se sienta “hinchado” y tenga dificultad para tragar. Estos efectos secundarios pueden durar 30 días o más y algunos pueden requerir una segunda cirugía para corregirlos.
- Los efectos secundarios graves, como infección o ataque al corazón, pueden ser más comunes con la cirugía que con los medicamentos. Estos efectos secundarios son raros.

### Tratamientos endoscópicos

Los tratamientos endoscópicos ayudan a fortalecer el músculo que evita que el alimento y el ácido suban al esófago. Estos tratamientos no se consideran cirugía, porque no requieren ningún corte en el abdomen. En lugar de eso, un médico introduce por la boca, hasta el esófago, un tubo delgado llamado endoscopio, para hacer el tratamiento.

Tres tipos de tratamientos endoscópicos son EndoCinch™, Stretta^®^ y EsophyX™. Estos tratamientos son muy nuevos y no son tan comunes como los medicamentos o la cirugía para tratar la ERGE. Las personas que reciben uno de estos tratamientos puede que participen en un estudio para evaluar su efectividad.

#### ¿Qué dicen las investigaciones sobre los tratamientos endoscópicos?

- No existen estudios suficientes para saber qué tan bien funcionan los tratamientos endoscópicos (EndoCinch™, Stretta^®^ y EsophyX™) para controlar los síntomas de la ERGE.

#### ¿Qué efectos secundarios causan los tratamientos endoscópicos?

- Los tratamientos endoscópicos pueden causar dolor en el pecho o el abdomen y sangrado.
- Pueden también causar que se sienta “hinchado” y dificultad para tragar. Estos efectos secundarios pueden durar 30 días o más.
- Como estos tratamientos son nuevos, no existe suficiente investigación para evaluar su seguridad.

### Cambios en el estilo de vida

Su médico puede sugerir algunos cambios en el estilo de vida que puedan ayudarle a controlar los síntomas de la ERGE. Entre ellos están:

- Mantener un peso sano.
- Dejar de fumar.
- Limitar las bebidas alcohólicas.
- Evitar comer 3 horas antes de acostarse.
- Elevar la cabecera de la cama.
- Evitar los alimentos que puedan empeorar los síntomas de la ERGE (los picantes y grasosos, la menta, el chocolate, comidas a base de tomate, el café y los frutos cítricos).

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Debe considerar varias cosas al elegir un tratamiento:

- Los riesgos y beneficios de cada tratamiento.
- El costo de cada tratamiento.
- Qué tratamiento se ajusta mejor a lo que le gusta, no le gusta y sus valores.

#### ¿Cuáles son los costos del tratamiento?

El costo que tengan para usted estos medicamentos depende de:

- El tipo de seguro médico que tenga.
- La dosis (cantidad) que necesite tomar.
- Si el medicamento existe en versión genérica o se vende sin receta. Muchos H2RA y PPI se venden sin receta, pero su seguro puede que no cubra el costo si los compra de esa forma.

Precios de mayoreo de medicamentos con receta para la ERGE

Nombre del medicamento | Dosis | Frecuencia | Precio mensual del genérico^*^ | Nombre comercial | Precio mensual del comercial^*^
H2RAs
Famotidina | 20 mg | Dos veces al día | $123 | ND | ND
Nizatidina | 150 mg | Dos veces al día | $145 | Axid^®^ | $203
Ranitidina | 150 mg | Dos veces al día | $24 | Zantac^®^ | $273
Cimetidina | 400 mg | Cuatro veces al día | $240 | Tagamet^®^ | $260
Cimetidina | 800 mg | Dos veces al día | $170 | Tagamet^®^ | $260
PPI
Omeprazol | 20 mg | Una vez al día | $177 | Prilosec^®^ | $200
Omeprazol | 40 mg | Una vez al día | $222 | Prilosec^®^ | $296
Omeprazol con bicarbonato de sodio | 20 mg | Una vez al día | $194 | Zegerid^®^ | $194
Omeprazol con bicarbonato de sodio | 40 mg | Una vez al día | $271 | Zegerid^®^ | $271
Lansoprazol | 15 mg | Una vez al día | $175 | Prevacid^®^ | $212
Lansoprazol | 30 mg | Una vez al día | $177 | Prevacid^®^ | $202
Pantoprazol | 20 mg | Una vez al día | $123 | Protonix^®^ | $176
Pantoprazol | 40 mg | Una vez al día | $171 | Protonix^®^ | $176
Rabeprazol | 20 mg | Una vez al día | ND | Aciphex^®^ | $249
Esomeprazol | 20 mg | Una vez al día | ND | Nexium^®^ | $207
Esomeprazol | 30 mg | Una vez al día | ND | Nexium^®^ | $414
Esomeprazol | 40 mg | Una vez al día | $161 | Nexium^®^ | $207
Dexlansoprazol | 30 mg | Una vez al día | ND | Dexilant^®^ | $142
Dexlansoprazol | 60 mg | Una vez al día | ND | Dexilant^®^ | $142

* Precios de mayoreo obtenidos de la edición 2011 del Red Book: Los precios del medicamento genérico son el promedio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia. ND = no disponible.

#### Costos de los medicamentos sin receta para la ERGE

El costo de los medicamentos sin receta varía según el establecimiento que los venda. La mayoría cuestan entre $13 y $30 al mes, dependiendo de la marca y de la cantidad que se use.

#### Pregunte a su médico

- ¿Qué debemos considerar al decidir qué tratamiento es el mejor para mí?
- Si los medicamentos son el mejor tratamiento, ¿importa si los compro sin receta o con una receta suya?
- ¿En cuánto tiempo empezaré a sentirme mejor?
- ¿Qué hago si persiste la acidez estomacal después del tratamiento?
- ¿Cómo decidiremos si necesito cirugía y cuándo?
- ¿Bajar de peso o hacer otros cambios en mi estilo de vida pueden ayudar a aliviar los síntomas de la ERGE? ¿En tal caso, cómo lo hago?

Otras preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Management Strategies for Adults With Gastroesophageal Reflux Disease — An Update (Estrategias de tratamiento para adultos con enfermedad por reflujo gastroesofágico: actualización). El informe fue preparado por el Tufts Center Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Centro Médico de la Universidad Tufts), para la Agency for Healthcare Research and Quality (AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov (disponible sólo en inglés). Se obtuvo información adicional de la página web Medline-Plus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor), de Houston, TX.