# La enfermedad de reflujo gastroesofágico o GERD (por sus siglas en inglés)

## ¿Padece usted de GERD o reflujo gastroesofágico?

El esófago es el tubo que lleva el alimento de la garganta al estómago. El estómago crea ácido para digerir los alimentos. Algunas veces el ácido puede subirse al esófago. Esto puede causar síntomas como ardor estomacal o hasta sabor amargo en el paladar. Cuando esto ocurre y por un período de tiempo largo, se le conoce como GERD o reflujo gastroesofágico.

Muchas personas padecen de ardor estomacal de vez en cuando. Otras padecen de un GERD que no es tan grave. Para mantener el GERD bajo control se deben realizar cambios en su estilo de vida. Los antiácidos u otros medicamentos sin receta también pueden ser de ayuda.

Esta información es para personas que padecen de un GERD severo y están siendo tratados por un médico u otro proveedor de atención médica. Lleve esta información consigo cuando usted y su proveedor decidan como tratar su GERD.

## ¿Qué tipo de medicamentos puedo tomar para el GERD?

La mayoría de los medicamentos para tratar el GERD trabajan para disminuir el nivel de ácido en el estómago. Los dos tipos principales de medicamentos con prescripción son:

- Los antagonistas receptores de H2 ó H2RAs. Ejemplos de estos son: Axid, Pepcid, Tagamet y Zantac.
- Los inhibidores de bombeo de protones o PPIs (por sus siglas en inglés) son: AcipHex, Nexium, Prevacid, Prilosec OTC y Protonix. También está disponible el omeprazole genérico.

Los PPIs funcionan mejor que los medicamentos H2RA para tratar el GERD. Sin embargo, los PPIs tienen una mayor probabilidad de causar efectos secundarios tales como dolores de cabeza o diarrea.

Los estudios demuestran que en general cada PPI funciona tan bien como el otro para aliviar los síntomas.

## ¿Puede ayudar la cirugía?

Para tratar el GERD se puede llevar a cabo una cirugía. En la cirugía, la parta superior del estómago se pliega alrededor de la parte inferior del esófago. Esto ayuda a prevenir que el ácido suba del estómago.

El efecto secundario común de la cirugía consiste en la dificultad para tragar y la hinchazón. Es raro pero problemas más serios pueden ocurrir.

Los medicamentos con prescripción por sí solos pueden funcionar tan bien como la cirugía para aliviar los síntomas. Algunas personas que se hacen la cirugía aún así tienen que tomar medicamentos.

## ¿Y qué sobre los procedimientos endoscópicos nuevos?

El endoscopio es un tubo que va desde la boca hasta el esófago. Utilizando el lente, los médicos pueden tratar la parte inferior del esófago para mejorar su funcionamiento. Estos procedimientos que no involucran cirugía son un poco nuevos. No existe evidencia científica suficiente aún para decir si funcionan bien.

## Para más información

Estos hallazgos provienen de un reporte en inglés que compara los tratamientos para el GERD. Usted puede encontrar el reporte pulsando www.effectivehealthcare.ahrq.gov.

Usted puede encontrar más información sobre el GERD en http://www.healthfinder.gov/espanol/ y http://medlineplus.gov/spanish/. Estos recursos le brindarán enlaces a sitios Web de salud de muchos grupos gubernamentales y sin fines de lucro.

## Related Content

Research Review

Consumer Guide