# Opciones de tratamiento si su antidepresivo SSRI no es eficaz

## ¿Es este resumen apropiado para mí?

### Esta información es apropiada para usted si

- Su médico^*^ le dijo que tiene usted trastorno depresivo grave, un tipo de depresión que dura más de 2 semanas.
- Usted ha tomado uno de los medicamentos antidepresivos siguientes por un mínimo de 6 semanas^†^ y su depresión no mejora. Estos medicamentos son un tipo de antidepresivos llamados inhibidores selectivos de la recaptación de serotonina (SSRI, por su sigla en inglés). Tenga en cuenta que no todos los antidepresivos son SSRI.
  - Citalopram (Celexa^®^)
  - Escitalopram (Lexapro^®^)
  - Fluoxetina (Prozac^®^, Prozac Weekly^®^, Sarafem^®^)
  - Fluvoxamina (Luvox^®^, Luvox CR^®^)
  - Paroxetina (Paxil^®^, Paxil CR^®^, Pexeva^®^)
  - Sertralina (Zoloft^®^)
- Desea conocer otras opciones para tratar su depresión, para poder hablar al respecto con su médico.
- Y es mayor de 18 años de edad. Esta información proviene de investigaciones en adultos.

### ¿Qué cubre este resumen?

Este resumen habla de sus opciones para tratar la depresión si su SSRI ha tenido poca o ninguna eficacia. Hay muchas opciones eficaces para tratar la depresión. Pero no existen investigaciones suficientes para saber con certeza qué opción sería la mejor cuando un SSRI resulta poco o nada eficaz. Este resumen puede ayudarle a hablar con su médico sobre cuál es el proximó tratamiento a probar.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 44 estudios publicados entre enero de 1980 y abril de 2011 acerca de tratamientos para la depresión después de haber tomado un SSRI. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/ssri-depression.cfm (disponible sólo en inglés).

Si sus síntomas de depresión no mejoraron mientras tomaba un SSRI, usted no está solo. Hay otras opciones para tratar su depresión.

## Conozca su condición

### ¿Qué es la depresión?

La depresión es una enfermedad que afecta al cerebro. En Estados Unidos, aproximadamente una de cada cinco personas tiene depresión alguna vez en la vida. La depresión puede pasar de una generación a otra en una misma familia. La química de su cerebro o factores ambientales como el estrés, también pueden causar la depresión.

La depresión no es lo mismo que sentirse triste o desanimado de vez en cuando. Las personas con depresión sienten tristeza, falta de energía, cansancio o tienen dificultad para disfrutar sus actividades, casi todos los días.

No todas las personas que tienen depresión se sienten tristes o con falta de ánimo. Otros síntomas de depresión pueden ser:

- Cambios en sus hábitos de sueño, como dormir poco o dormir más de lo habitual
- Menos interés en las actividades que usualmente disfruta
- Comer menos o más que antes, ya sea que se tenga o no hambre
- Sentimientos intensos de desesperación
- Falta de autoestima o desesperanza
- Dificultad para pensar o concentrarse
- Sentimiento de culpa excesiva o sin razón
- Pensamientos suicidas

La depresión es un problema serio, pero tratable, que no debe desatenderse. Existen muchas opciones de tratamiento para las personas con depresión.

Si en algún momento tiene pensamientos de hacerse daño o suicidarse, llame inmediatamente a su médico. La Red Nacional de Prevención del Suicidio está disponible en el 1-800-273-TALK (8255), o visite http://www.suicidepreventionlifeline.org/gethelp/spanish.aspx

### ¿Qué es un SSRI y por qué lo estoy tomando?

Los inhibidores selectivos de la recaptación de serotonina (SSRI) son un tipo de medicamento antidepresivo. Los SSRI son uno de los tipos de medicamentos que más utilizan las personas con depresión. Para ejercer su efecto, los SSRI modifican una sustancia química del cerebro llamada serotonina. La serotonina le ayuda a controlar su estado de ánimo y lo hace sentirse contento.

### ¿Por qué un SSRI no me fue eficaz?

Los síntomas de depresión desaparecen por completo en aproximadamente una de cada tres personas que toman un SSRI. Los médicos no saben por qué los SSRI son eficaces en algunas personas y no en otras. Si un SSRI no le es eficaz, su médico puede sugerirle que pruebe otros tratamientos.

Asegúrese de avisar a su médico si hay algo que le haya impedido tomar su SSRI (como el costo demasiado alto, la dificultad para acordarse de tomarlo o efectos secundarios). Es importante que nunca deje de tomar su medicamento, ni cambie la cantidad que toma, sin antes preguntar al médico.

## Conozca sus opciones

### ¿Qué tratamientos hay disponibles si un SSRI no es eficaz?

Hay muchas opciones que un médico puede sugerir a las personas cuyos síntomas de depresión no mejoran lo suficiente con el tratamiento de SSRI:

- Aumentar la dosis (cantidad) del SSRI que toma.
  - Es importante no aumentar nunca la cantidad de su medicamento si no se lo pide el médico.
- Cambiar a un SSRI diferente.
- Cambiar a un tipo diferente de antidepresivo que no sea SSRI, como bupropión (Wellbutrin^®^), desvenlafaxina (Pristiq^®^), duloxetina (Cymbalta^®^) o venlafaxina (Effexor^®^).
- Añadir un medicamento antipsicótico a su SSRI, como aripiprazol (Abilify^®^), olanzapina (Zyprexa^®^) o quetiapina XR (Seroquel XR^®^).
  - Para ejercer su efecto, los medicamentos antipsicóticos modifican la forma en que ciertas sustancias químicas actúan en el cerebro. El hecho de que tome un medicamento antipsicótico no significa que tiene psicosis.
  - La Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos ha aprobado las siguientes combinaciones de medicamentos antipsicóticos y antidepresivos para tratar a los pacientes con depresión:
    - Aripiprazol (Abilify^®^) o quetiapina XR (Seroquel XR^®^), añadidos a cualquier antidepresivo
    - Olanzapina (Zyprexa^®^), añadida al SSRI fluoxetina (Prozac^®^, Prozac Weekly^®^, Sarafem^®^)
- Considere un tratamiento sin medicamentos, por ejemplo:
  - Psicoterapia: En este tipo de tratamiento, un terapeuta^*^ capacitado habla con usted sobre lo que piensa y lo que siente respecto a su depresión. Puede usted hablar de determinados síntomas o sucesos de la vida, la forma de enfrentarlos o la manera de abordar los problemas. En ocasiones, el terapeuta realiza la psicoterapia con un grupo de personas (llamada “terapia de grupo”).
  - Ejercicio: Entre los mejores ejercicios están los que aumentan el ritmo cardíaco, fortalecen o sirven para estirar los músculos, como el yoga.

Nota: Para la depresión grave que interfiere con las actividades diarias de la persona, algunos médicos pueden sugerir “terapia electroconvulsiva” o “estimulación magnética transcraneal repetitiva”. Se pueden ver descripciones de estos tratamientos, en el resumen de investigación para el consumidor Therapies for Treatment-Resistant Depression (Terapias para la depresión resistente al tratamiento). Si desea un ejemplar gratis, llame al 800-358-9295 y pida la Publicación AHRQ Nº 11(12)-EHC056-B, o bien, descargue una copia para imprimir en http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productID=1130.

### ¿Pueden las investigaciones decirnos cuál de estos tratamientos es mejor?

Hay muchas opciones eficaces para tratar la depresión. Pero no existen investigaciones suficientes para saber con certeza que opción sería la mejor cuando un SSRI resulta poco o nada eficaz. Hable con su médico sobre sus opciones y cuál es el próximo tratamiento que debe probar. Los tratamientos actúan en forma diferente en cada persona. Es posible que tenga que probar varios tratamientos antes de encontrar el que le sea más eficaz.

### ¿Cuáles son los efectos secundarios posibles de estos tratamientos?

La FDA lista los siguientes efectos secundarios posibles que pueden causar los medicamentos antidepresivos y antipsicóticos. No todas las personas que toman uno de estos medicamentos tendrán efectos secundarios. Muchos de estos efectos secundarios son temporales. Su médico puede sugerir formas de reducir cualquier efecto secundario que pueda tener. Nunca deje de tomar su medicamento sin antes preguntar a su médico.

Los antidepresivos pueden causar
- Dolores de cabeza
- Resequedad en la boca
- Mareos o desmayo
- Problemas sexuales
- Ansiedad
- Sentirse con poca alegría (embotado) o sensación
- Aumento de peso
- Problemas del sueño
- Sentirse cansado o con poca energía
- Malestar estomacal
- Considerar o intentar el suicidio

Los medicamentos antipsicóticos pueden causar
- Aumento de peso
- Colesterol alto o diabetes, que pueden resultar por el aumento de peso
- Movimientos incontrolables, como tics y temblores
- Presión arterial baja
- Dificultad para tragar
- Convulsiones
- Sueño excesivo
- Mareos
- Dolores de cabeza
- Resequedad en la boca
- Estreñimiento
- Aumento de una hormona en el cuerpo llamada prolactina, que puede causar problemas de la función sexual y agrandamiento de los senos en hombres y mujeres

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varios factores al decidir con su médico cómo tratar su depresión si su SSRI no está siendo eficaz, tales como:

- Los beneficios y efectos secundarios posibles de cada tratamiento
- Qué tratamiento se adapta mejor a su estilo de vida y valores
- El costo para usted de cada tratamiento

Hable con su médico sobre lo que es importante para usted, al decidir cómo tratar su depresión. Tal vez desee hablar de:

- Qué síntomas no mejoraron mientras estuvo tomando un SSRI
- Cualquier inquietud que tenga sobre los posibles efectos secundarios de los medicamentos
- Si un tratamiento sin medicamentos podría ayudar a tratar su depresión
- Qué aspectos de su vida o actividades pueden hacer que una opción de tratamiento le sea más fácil o más difícil

### ¿Cuáles son los costos del tratamiento?

El costo para usted de los medicamentos para tratar su depresión depende de:

- Su seguro médico
- La dosis (cantidad) que necesite tomar
- Si el medicamento existe en forma genérica

### Pregunte a su médico

- ¿Cuál es el próximo tratamiento que usted considera que debo probar? ¿Por qué?
- ¿Cuánto tiempo tendremos que esperar para ver si este nuevo tratamiento es eficaz?
- Si decido tomar un medicamento para mi depresión, ¿por cuánto tiempo necesitaré tomarlo?
- ¿Afectará mi medicamento para la depresión a alguno de los otros medicamentos que tomo?
- ¿Qué posibilidad hay de que se presente algún efecto secundario por tomar mi medicamento para la depresión?
- Si estoy embarazada o quiero estarlo en un futuro, ¿puedo seguir tomando mi medicamento para la depresión?
- ¿Qué efectos secundarios me deben preocupar más?
- ¿Cuándo debo avisarle de algún efecto secundario que tenga?
- ¿Qué haremos si el tratamiento que me propone ahora no me hace sentir mejor?

## Fuente

La información de este resumen proviene del informe Treatment for Depression After Unsatisfactory Response to SSRIs (Tratamiento de la depresión después de respuesta insatisfactoria con los SSRI), de abril de 2012. Fue producido por el McMaster University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de McMaster), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/ssri-depression.cfm (disponible sólo en inglés). Otra información proviene de las etiquetas de los medicamentos aprobados por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) y la página web de MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. La página web de MedlinePlus^®^ está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con depresión.

Esta guía fue traducida de la publicación en inglés titulada Treatment Options When Your SSRI Antidepressant Is Not Working Well.

* En este resumen, el término “médico” se refiere a los profesionales de atención médica que lo atienden, como puede ser su médico general, psiquiatra, terapeuta, enfermera o asistente médico.

† Los SSRI pueden tardar hasta 6 semanas en empezar a actuar.

* El término “terapeuta capacitado” se refiere a profesionales de la atención médica que tienen una licencia, como los psicólogos, trabajadores sociales, terapeutas para pareja y familiares o los psiquiatras.