# Uso de suplementos dietéticos junto con medicamentos para el corazón, la presión arterial o el colesterol

Revisión de la investigación para adultos

## ¿Es este resumen apropiado para mí?

### Sí, esta información es para usted si

- Su médico^*^ le ha sugerido tomar uno de los medicamentos de la lista siguiente para el corazón, los vasos sanguíneos, la presión arterial, el colesterol o para diluir la sangre. Se llaman medicamentos cardiovasculares (CV).
  - Medicamentos para controlar la presión arterial, como los inhibidores de la enzima convertidora de angiotensina (ECA), los bloqueadores del receptor de angiotensina (BRA) II, los bloqueadores beta, los bloqueadores del canal del calcio y los diuréticos^**^
  - Medicamentos que aumentan la fuerza de bombeo del corazón, como Lanoxicaps^®^ o Lanoxin^®^
  - Medicamentos que ayudan a controlar sus niveles de colesterol y de triglicéridos, como las estatinas o el fenofibrato
  - Diluyentes de la sangre, como la warfarina (Coumadin^®^)
  - Aspirina u otros medicamentos “antiplaquetarios”, como Plavix^®^, Brilinta^®^ o Pradaxa^®^
  - Medicamentos para tratar o prevenir el dolor de pecho en el corazón, como los nitratos, tales como Isordil^®^
- Quiere saber qué dicen las investigaciones acerca del uso conjunto de suplementos dietéticos y medicamentos CV.
- Tiene 18 años de edad o más. La información para este resumen proviene de investigación realizada en adultos.
- Está tomando o considerando tomar uno o más suplementos dietéticos (vitaminas, minerales, hierbas u otras sustancias que complementen las vitaminas y minerales que obtiene de los alimentos), además de su medicamento CV.^†^ Los suplementos dietéticos estudiados en la investigación para preparar este resumen son:
  - Niacina (vitamina B3)
  - Vitamina E
  - Vitamina K
  - Magnesio
  - Ginseng
  - Equinácea
  - Suplementos de ajo
  - Suplementos de jengibre
  - Ginkgo biloba
  - Ácidos grasos omega-3 o aceite de pescado
  - Coenzima Q10
  - Espino blanco

### ¿Qué cubre este resumen?

Este resumen explica que no existe suficiente investigación sobre el uso conjunto de suplementos dietéticos y medicamentos CV, para saber con certeza si los suplementos son beneficiosos o dañinos. Los suplementos dietéticos pueden tomarse por muchas razones además de problemas CV. Este resumen se ocupa solamente de las investigaciones sobre el uso de determinados suplementos dietéticos junto con los medicamentos CV. Este resumen puede ayudarle a hablar con su médico sobre el uso de suplementos dietéticos.

### ¿De dónde proviene la información de este resumen?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica;AHRQ, por su sigla en inglés), organismo de investigación del Gobierno Federal, revisaron 70 estudios publicados hasta septiembre de 2011 acerca de los efectos del uso conjunto de suplementos dietéticos y medicamentos cardiovasculares (CV). El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/dietary-supplements.cfm (disponible sólo en inglés).

## Conozca la enfermedad cardiovascular

### ¿Qué es la enfermedad cardiovascular?

Se llama enfermedad cardiovascular (CV) a toda enfermedad que afecte al corazón y los vasos sanguíneos. Un tipo frecuente de enfermedad CV ocurre cuando los vasos sanguíneos que suministran sangre al corazón se estrechan o se obstruyen. Ésta es la causa principal de los ataques al corazón y la insuficiencia cardiaca. La presión arterial alta o el colesterol alto pueden aumentar el riesgo de padecer de enfermedad CV y podrían ocasionar un ataque cardiaco. Su médico puede prescribir medicamentos para tratar la presión arterial alta o el colesterol alto, para evitar que usted padezca de enfermedad CV.

Pueden ocurrir otros problemas cardiacos cuando las válvulas del corazón no funcionan correctamente o cuando el corazón no bombea adecuadamente la sangre. Estos problemas pueden ocasionar insuficiencia cardiaca.

### ¿Qué tan frecuente es la enfermedad CV?

- Aproximadamente 1 de cada 3 adultos en Estados Unidos (unos 81 millones de estadounidenses) tiene algún tipo de enfermedad CV.
- La enfermedad CV es la principal causa de muerte en Estados Unidos.

### ¿Cómo se previene o se trata la enfermedad CV?

Los cambios en el estilo de vida, como comer sanamente, hacer ejercicio y no fumar, pueden mejorar la presión arterial y el colesterol. Esto puede ayudar a prevenir la enfermedad CV o evitar que empeore. Hay también muchos medicamentos para tratar los problemas CV. Entre ellos están medicamentos que:

- Disminuyen la presión arterial
- Reducen el colesterol y los triglicéridos (un tipo de grasa presente en la sangre)
- Ayudan al corazón a bombear con mayor fuerza
- Evitan la formación de coágulos de sangre.

Las personas con enfermedad CV toman un promedio de seis medicamentos para tratar esta condición.

## Conozca sus opciones

### ¿Qué son los suplementos dietéticos?

Los suplementos dietéticos son vitaminas, minerales, hierbas u otras sustancias que refuerzan (o “complementan”) las vitaminas y minerales que usted obtiene de los alimentos. Estos productos vienen en forma de pastillas, polvos, bebidas y barritas. Se venden en farmacias, supermercados, tiendas de vitaminas, tiendas de alimentos naturales y por Internet.

Muchos suplementos se anuncian para tratar problemas de salud específicos, como la presión arterial alta, el colesterol alto o la enfermedad CV. Algunos suplementos que se han vendido para aliviar estos problemas CV son:

- Vitaminas y minerales, tales como:
  - Niacina (vitamina B_3_)
  - Vitamina E
  - Vitamina K
  - Magnesio
- Hierbas o suplementos derivados de plantas; por ejemplo:
  - Ginseng
  - Equinácea
  - Suplementos de jengibre
  - Ginkgo biloba
  - Espino blanco
  - Suplementos de ajo
- Otros suplementos, como:
  - Ácidos grasos omega-3 o aceite de pescado
  - Coenzima Q10

Los suplementos dietéticos son muy conocidos. Quizá los haya visto anunciados en la TV, en Internet, en periódicos o en revistas. O bien, tal vez ha oído de suplementos a través de un amigo. De cada tres adultos con problemas CV, entre uno y dos toman algún suplemento dietético porque suponen que beneficiará su salud.

Puede encontrar más información sobre los suplementos dietéticos, en:

- La página web de la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos: www.fda.gov/Food/DietarySupplements/UsingDietarySupplements/ucm210723.htm (en español)
- La página web de los National Institutes of Health (Institutos Nacionales de la Salud): http://ods.od.nih.gov/HealthInformation/lo_que_usted_necesita_saber.aspx (en español)

### ¿En qué difieren los suplementos dietéticos de los medicamentos con y sin receta?

Los suplementos dietéticos que se compran sin receta y aseguran mejorar condiciones como la presión arterial alta, el colesterol alto o la enfermedad CV, no son lo mismo que medicamentos.^*^ Los suplementos no están pensados para tratar, prevenir ni curar enfermedades.

A diferencia de los medicamentos de venta con y sin receta, los suplementos dietéticos no tienen que ser aprobados por la FDA.

- Los medicamentos de venta con o sin receta deben someterse a pruebas que demuestren su eficacia y su seguridad antes de poder anunciarse y venderse al público.
- En cambio, los suplementos dietéticos no tienen que demostrar eficacia ni seguridad antes de anunciarse y venderse. Se piensa que los suplementos son seguros porque la gente los ha utilizado durante muchos años.

Nota: Consulte a su médico sobre la seguridad y los beneficios que afirman tener los suplementos dietéticos y si pueden ayudarle.

### ¿Pueden hacer daño los suplementos dietéticos?

Aunque los suplementos dietéticos se anuncian como beneficioso o útiles, no se ha hecho mucha investigación sobre cómo pueden afectar la salud cuando se toman junto con medicamentos CV. Los suplementos pueden causar efectos secundarios que tal vez no se mencionen en la etiqueta. Los suplementos dietéticos pueden también interferir con ciertos medicamentos o con otros suplementos. Eso podría hacer que el medicamento o el suplemento pierda eficacia o cause otros efectos secundarios.

Nota: Es importante que siempre informe a su médico de cualquier suplemento que tome. También es importante que siga tomando sus medicamentos CV y cualquier otro medicamento, tal como se lo haya indicado su médico, aun cuando tome también un suplemento dietético. Los suplementos dietéticos no sustituyen a los medicamentos con receta.

Nota: La FDA informa que la vitamina K en exceso puede hacer que la warfarina (Coumadin®) deje de actuar correctamente. Esto puede aumentar el riesgo de que se formen coágulos de sangre, de tener un ataque al corazón o un derrame. Si toma warfarina, asegúrese de consultar a su médico antes de tomar vitamina K.

### ¿Qué dicen las investigaciones acerca del uso de suplementos dietéticos junto con medicamentos CV?

No existe suficiente investigación para saber con certeza si los suplementos realmente ayudan o si causan algún daño cuando se toman junto con medicamentos CV.

- No existe suficiente investigación para saber con certeza si el uso de suplementos dietéticos junto con medicamentos CV ayuda a mejorar la enfermedad CV o ayuda a prevenir la muerte por enfermedad CV.
- No existe suficiente investigación para saber con certeza si el tomar suplementos junto con medicamentos CV ayuda a mejorar las condiciones que aumentan el riesgo de enfermedad CV, tales como la presión arterial alta, el colesterol alto o los niveles altos de triglicéridos.
- No existe suficiente investigación para saber con certeza si el tomar suplementos junto con medicamentos CV causa algunos efectos secundarios menores o graves. Los efectos secundarios pueden consistir en náusea, diarrea, estreñimiento, convulsiones, dificultad para respirar o para tragar, problemas de sangrado, problemas de los riñones o del hígado.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varios factores al decidir si se debe o no se debe añadir un suplemento dietético al medicamento CV. Hable con su médico sobre:

- Cuánto se sabe acerca de los beneficios y la seguridad del suplemento que desea tomar
- Si los suplementos dietéticos pueden interferir con otros medicamentos que toma además de su medicamento CV o afectar otras condiciones que padece
- Cómo interpretar correctamente lo que se afirma de los suplementos en los medios de comunicación y en Internet
- El costo de añadir suplementos dietéticos a su medicamento CV

### ¿Cuáles son los costos de los suplementos dietéticos?

Los costos para usted de los suplementos dietéticos varían mucho, dependiendo de:

- El tipo y la marca de los suplementos
- La tienda o la página web donde los compre
- La cantidad que ordene al momento de la compra

### Pregunte a su médico

Informe siempre a su médico si piensa tomar un suplemento dietético, antes de empezar. Debe preguntarle a su médico:

- ¿Qué piensa sobre agregar un suplemento dietético a mi medicamento CV? ¿Me ayudarían los suplementos?
- ¿Sería peligroso si tomo un suplemento dietético?
- ¿Qué suplementos dietéticos pueden interferir con los medicamentos que tomo?
- Si decido tomar un suplemento, ¿qué cantidad debo tomar? ¿Con qué frecuencia? ¿Durante cuánto tiempo?
- ¿A qué efectos secundarios debo estar atento?

## Fuente

La información de este resumen proviene del informe Dietary Supplement Use in Adults Taking Cardiovascular Drugs (Uso de suplementos dietéticos en adultos que toman medicamentos cardiovasculares), de abril de 2012. El informe fue producido por el University of Ottawa Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Ottawa), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/dietary-supplements.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes que toman medicamentos CV.

Esta guía fue traducida de la publicación en inglés titulada Taking Dietary Supplements With Heart, Blood Pressure, or Cholesterol Medicines: A Review of the Research for Adults.

* En este resumen, el término “médico” se refiere a los profesionales de la atención médica que pueden atenderlo, lo que incluye a su médico, cardiólogo, enfermera o asistente médico.

** Pueden encontrarse ejemplos de estos tipos de medicamentos, tomados por hombres y mujeres para controlar la presión arterial, en www.fda.gov/ForConsumers/ByAudience/ForWomen/ucm118594.htm (disponible sólo en inglés).

† No se estudiaron todos los suplementos dietéticos y medicamentos CV, sino sólo los que se mencionan en este resumen.

* Algunos suplementos se han convertido en medicamentos y están regulados por la FDA. Por lo general, tienen dosis y concentraciones más altas que los que se obtienen sin receta. Ejemplos de ellos son la niacina (vitamina B_3_) y los ácidos grasos omega-3 (Lovaza^®^).