# Medicamentos para la diabetes tipo 2

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Su médico o personal de atención médica le ha dicho que tiene diabetes tipo 2 y un nivel alto de azúcar en la sangre.
- Su médico o personal de atención médica le recomienda tomar medicamentos para ayudar a bajar o controlar su nivel de azúcar en la sangre.

### No es apropiada si

- Tiene usted menos de 18 años de edad.
- Tiene un tipo diferente de diabetes, llamada diabetes tipo 1.
- Está embarazada y tiene un tipo diferente de diabetes, llamada diabetes gestacional.

### ¿Qué cubre este resumen de investigación?

Este resumen cubre la investigación sobre los beneficios y posibles efectos secundarios de los medicamentos para bajar o para controlar el nivel de azúcar en la sangre. Le ayudará a hablar con su médico u otro profesional de la atención médica para decidir qué medicamentos son los mejores para usted.

### ¿De dónde proviene la información?

La información de esta guía proviene de una revisión de muchos estudios sobre los medicamentos para la diabetes tipo 2. La revisión fue efectuada por un centro de investigación independiente en 2007 y nuevamente en 2011. Lea el informe detallado en www.effectivehealthcare.ahrq.gov/diabetesmeds.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la diabetes tipo 2?

- La insulina es una hormona, o sustancia química, elaborada por el cuerpo. Es necesaria para transformar el alimento en energía.
- Tener diabetes tipo 2 significa que el cuerpo no puede producir suficiente insulina o que las células de su cuerpo no la utilizan bien. Esto causa que el azúcar en la sangre aumente demasiado.

### ¿Por qué es necesario tratar la diabetes tipo 2?

- Si su nivel de azúcar en la sangre se mantiene alto por mucho tiempo, puede aumentar la posibilidad de que ocurra un ataque al corazón, un derrame, daño a los riñones o ceguera. También puede necesitar que le amputen un dedo del pie, un pie o una pierna, debido a la mala circulación de la sangre.
- La posibilidad de tener esos problemas puede disminuir si el azúcar en la sangre se mantiene en un nivel adecuado.

### ¿Cómo se trata la diabetes tipo 2?

- El primer paso para controlar su nivel de azúcar en la sangre es comer una dieta balanceada y ser más activo. Hasta cambios pequeños con el ejercicio pueden servir de mucho.
- Mucha gente también necesita medicamentos para ayudarse a mantener controlado su nivel de azúcar en la sangre.

### ¿Cómo sé qué cantidad de azúcar tengo en la sangre?

Hay dos formas comunes de medir el azúcar en la sangre. Éstas pueden ayudarle a usted y a su médico a ver con qué efectividad se está controlando el azúcar en la sangre.

### Piquete o pinchazo en el dedo

Una de esas pruebas consiste en un piquete o pinchazo en el dedo (o antebrazo), que puede hacerse usted mismo. Esta prueba se hace una o más veces al día. Puede hacerla por la mañana antes de desayunar (en ayunas), o a otras horas del día; por ejemplo, después de una comida. Esta prueba indica el nivel de azúcar en la sangre en ese momento. La cifra en ayunas debe estar entre 80 y 120.

Después de una comida, el valor ideal suele ser de menos de 180.

### Prueba de sangre

La otra prueba es un análisis de sangre llamado prueba de hemoglobina (Hb) A1C.

Ésta se realiza en el consultorio o en un laboratorio, varias veces al año. La prueba A1C muestra el valor promedio del nivel de azúcar en la sangre durante los últimos 2 ó 3 meses. En general, el valor ideal del A1C es alrededor de 7.

Eso significa que su nivel de azúcar en la sangre, usando la prueba de punción del dedo, ha estado dentro del margen “bueno” durante los últimos 2 ó 3 meses. Si el nivel de A1C es más alto, tal vez convenga un cambio de medicamento.

## Conozca sus opciones

### ¿Son iguales todos medicamentos para la diabetes?

Existen muchos tipos de medicamentos para la diabetes. Cada tipo funciona de manera diferente para controlar el azúcar en la sangre.

### ¿Qué tan eficaces son los medicamentos para bajar el azúcar en la sangre?

Todos los medicamentos de este resumen bajan el azúcar en la sangre. La prueba de laboratorio para medir el nivel de azúcar en la sangre (A1C) es el mejor medio para saber qué tan eficaces son los medicamentos.

- La mayoría de los medicamentos para la diabetes pueden bajar aproximadamente 1 punto de su A1C. Eso significa, que si empieza con un A1C de 8, el tomar uno de estos medicamentos podría bajarlo a 7.
- El uso combinado de dos tipos de medicamentos para la diabetes puede bajar el azúcar en la sangre más que tomando sólo un tipo. La mayoría de las combinaciones de medicamentos pueden bajar aproximadamente 1 punto adicional. Esto significa, que si empieza con un A1C de 9 y lo baja a 8 con un tipo de medicamento, tal vez añadiendo un segundo medicamento pueda bajarlo a 7.
- No existe suficiente investigación sobre ciertos medicamentos como: nateglinida (Starlix^®^), exenatida (Byetta^®^) y sitagliptina (Januvia^®^). Eso significa que no tenemos suficiente conocimiento sobre cómo estos medicamentos se comparan con otros medicamentos para la diabetes.

### Beneficios de los medicamentos para la diabetes tipo 2

Tipo de medicamento
Nombre genérico | Nombre comercial | Beneficios
Biguanidas Impiden al hígado elaborar azúcar.
Metformina | Glucophage^®^ | - Baja el A1C aproximadamente 1 punto; - Baja el colesterol “malo” más que otros tipos
Sulfonilureas Aumentan la cantidad de insulina en el cuerpo
Glimepirida | Amaryl^®^ | - Baja el A1C aproximadamente 1 punto
| | - Baja el A1C aproximadamente 1 punto
Glipizida | Glucotrol^®^ | - Baja el A1C aproximadamente 1 punto
| | - Baja el A1C aproximadamente 1 punto
Gliburida | Diabeta^®^ | - Baja el A1C aproximadamente 1 punto
| Glynase Prestab^®^ | - Baja el A1C aproximadamente 1 punto
| Micronase^®^ | - Baja el A1C aproximadamente 1 punto
Meglitinidas Aumentan la cantidad de insulina en el cuerpo
Repaglinida | Prandin^®^ | - Baja el A1C aproximadamente 1 punto
| | - Baja el A1C aproximadamente 1 punto
Nateglinida | Starlix^®^ | - Baja el A1C aproximadamente 1 punto
Tiazolidinedionas (TZD) Ayudan al organismo a utilizar mejor la insulina
Pioglitazona | Actos^®^ | - Baja el A1C aproximadamente 1 punto; - Baja los triglicéridos (una clase de grasa presente en la sangre) más que otros tipos; - Puede proteger la función de los riñones
Inhibidores de la dipeptidil peptidasa-4 (DPP-4) Aumentan la cantidad de insulina en el cuerpo después de una comida
Sitagliptina | Januvia^®^ | - Baja el A1C menos de 1 punto
| | - Baja el A1C menos de 1 punto
Saxagliptina | Onglyza^®^ | - Baja el A1C menos de 1 punto
Agonistas del receptor del péptido-1 glucagonoide (GLP-1) Aumentan la cantidad de insulina en el cuerpo
Exenatida | Byetta^®^ | - Menos aumento de peso que otros medicamentos; - Se sabe menos sobre la eficacia de este medicamento para bajar el A1C, en comparación con otros medicamentos
| | - Menos aumento de peso que otros medicamentos; - Se sabe menos sobre la eficacia de este medicamento para bajar el A1C, en comparación con otros medicamentos
Liraglutida | Victoza^®^ | - Menos aumento de peso que otros medicamentos; - Se sabe menos sobre la eficacia de este medicamento para bajar el A1C, en comparación con otros medicamentos
Combinaciones
Gliburida/metformina | | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
| | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
Metformina/pioglitazona | | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
| | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
Metformina/sitagliptina | | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
| | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
Metformina/saxagliptina | | - Baja el A1C aproximadamente 2 puntos; - La metformina/pioglitazona baja los triglicéridos
Metformina + agonistas del receptor del GLP-1 | | - La combinación metformina + agonistas del receptor del GLP-1 puede causar menos aumento de peso que otras combinaciones
| | - La combinación metformina + agonistas del receptor del GLP-1 puede causar menos aumento de peso que otras combinaciones
Metformina + insulina basal | | - La combinación metformina + agonistas del receptor del GLP-1 puede causar menos aumento de peso que otras combinaciones
| | - La combinación metformina + agonistas del receptor del GLP-1 puede causar menos aumento de peso que otras combinaciones
Metformina + insulina premezclada | | - La combinación metformina + agonistas del receptor del GLP-1 puede causar menos aumento de peso que otras combinaciones

Algunas combinaciones de medicamentos vienen en una sola pastilla, en cuyo caso los nombres de los medicamentos se muestran ligados por el símbolo “/”. Otros se toman juntos pero los medicamentos vienen separados, y se muestran ligados por el signo “+”.

### Posibles efectos secundarios de los medicamentos para la diabetes tipo 2

Tipo de medicamento
Nombre genérico | Nombre comercial | Posibles efectos secundarios
Biguanidas
Metformina | Glucophage^®^ | - Cierto riesgo de bajar demasiado el nivel de azúcar en la sangre; - Menos aumento de peso que con otros medicamentos; - Riesgo más alto de problemas estomacales (gases, diarrea)
Sulfonilureas
Glimepirida | Amaryl^®^ | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
| | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
Glipizida | Glucotrol^®^ | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
| | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
Gliburida | Diabeta^®^ | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
| Glinasa Prestab^®^ | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
| Micronase^®^ | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
| | - Puede causar aumento de peso; - 3 a 5 veces más probable de causar niveles bajos de azúcar en la sangre; - Puede causar problemas estomacales
Meglitinidas
Repaglinida | Prandin^®^ | - Puede causar aumento de peso; - Riesgo de bajar demasiado el azúcar en la sangre
| | - Puede causar aumento de peso; - Riesgo de bajar demasiado el azúcar en la sangre
Nateglinida | Starlix^®^ | - Puede causar aumento de peso; - Riesgo de bajar demasiado el azúcar en la sangre
Tiazolidinedionas (TZD)^*^
Pioglitazona | Actos^®^ | - Puede causar aumento de peso; - Cierto riesgo de bajar demasiado el azúcar en la sangre; - Puede aumentar el riesgo de insuficiencia cardiaca o empeorarla; - Aumenta el riesgo de fracturas, especialmente en las mujeres; - Puede causar cáncer de la vejiga cuando se usa por más de 1 año
Inhibidores de la dipeptidil peptidasa-4 (DPP-4)
Sitagliptina | Januvia^®^ | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
| | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
Saxagliptina | Onglyza^®^ | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
Agonistas del receptor del péptido-1 glucagonoide (GLP-1)
Exenatida | Byetta^®^ | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
| | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
Liraglutida | Victoza^®^ | - No se tiene suficiente conocimiento sobre los efectos secundarios de estos medicamentos
Combinaciones
Gliburida/metformina | | - Algunas combinaciones de medicamentos como las sulfonilureas, pueden aumentar el riesgo de un nivel bajo de azúcar en la sangre; - Las combinaciones de pioglitazona pueden causar un mayor aumento de peso que otros medicamentos; - Las combinaciones de pioglitazona pueden aumentar el riesgo de fractura de cadera y otras fracturas, especialmente en las mujeres; - Algunas combinaciones con metformina aumentan el riesgo de problemas estomacales, pero no tanto como la metformina sola
Metformina/pioglitazona
Metformina/sitagliptina
Metformina/saxagliptina
Metformina + agonistas del receptor del GLP-1
Metformina + insulina basal
Metformina + insulina premezclada

* NOTA: Su médico ha recibido una alerta de la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos, notificando que los pacientes con insuficiencia cardiaca grave no deben tomar TZD (pioglitazona o rosiglitazona).

La rosiglitazona también aumenta el riesgo de ataque al corazón y derrame.

Según la FDA, la rosiglitazona debe utilizarse solamente si otros medicamentos no logran bajarle el azúcar en la sangre. Hable con su médico.

### ¿Por qué el diagrama incluye información sobre el colesterol y los triglicéridos?

Los medicamentos para la diabetes se usan esencialmente para bajar el nivel de azúcar en la sangre. Las investigaciones indican que algunos pueden también afectar el colesterol y los triglicéridos.

#### Colesterol

- Todos debemos esforzarnos por mantener lo más bajo posible el colesterol “malo” (colesterol LDL). El colesterol malo puede tapar las arterias y producir un ataque cardiaco o un derrame cerebral. Las personas con diabetes tienen mayor riesgo de sufrir estos problemas. Su médico puede decirle si su LDL está demasiado alto.
- La mayoría de los medicamentos para la diabetes no suben ni bajan lo suficiente el colesterol “bueno” (colesterol HDL) como para afectar su salud. El colesterol bueno ayuda al cuerpo, no tapa las arterias, ni causa problemas del corazón.

#### Triglicéridos

- Los “triglicéridos” son un tipo de grasa que se encuentra en la sangre. El cuerpo elabora triglicéridos. También se encuentran en los alimentos. El cuerpo necesita este tipo de grasa, pero es mejor mantener bajo el nivel de los triglicéridos. La meta suele ser menos de 150.

### ¿Qué más debo saber sobre efectos secundarios graves?

Los efectos secundarios más frecuentes de los medicamentos para la diabetes tipo 2 son el aumento de peso y problemas estomacales. En el diagrama de la página 5 se mencionan otros efectos secundarios que no son comunes pero que pueden ser graves. Aquí se ofrece más información sobre algunos de ellos, para que pueda conversar con su médico, si algo le preocupa.

#### Nivel bajo de azúcar en la sangre

A veces, los medicamentos pueden bajar demasiado el azúcar en la sangre. Esto se conoce como “hipoglucemia”. Un nivel bajo de azúcar en la sangre puede causarle mareos, sudor frío, confusión, temblores y debilidad.

- El nivel bajo de azúcar en la sangre es más probable cuando se toman dos o más tipos de medicamentos para la diabetes.

Advertencia: Si piensa que tiene el azúcar en la sangre bajo, coma o tome inmediatamente algo con azúcar. Si los síntomas surgen cuando está manejando o usando una máquina, deténgase en el hombro lateral de la carretera o apague la máquina. Tal vez quiera llevar siempre consigo un jugo o caramelos, hasta que se sienta más cómodo con su medicamento. Pregunte a su médico.

#### Acidosis láctica

El uso de medicamentos para la diabetes puede aumentar la posibilidad de que ocurra una condición rara llamada “acidosis láctica”. Esta condición ocurre con más frecuencia en las personas que toman medicamentos para la diabetes y tienen problemas de los riñones o del hígado. Cada año, cerca de 1 de cada 10,000 personas que toman medicamentos para la diabetes padecerá de acidosis láctica. Los signos comunes de la acidosis láctica son:

- Dificultad para respirar.
- Vómito o dolor de estómago.
- Debilidad o dolor muscular inusual.
- Escalofríos o mareos.

La posibilidad de padecer de acidosis láctica es casi la misma con todos los medicamentos para la diabetes.

Advertencia: Si tiene usted cualquier signo de acidosis láctica, llame de inmediato a su médico o enfermera.

### Insuficiencia cardiaca

La insuficiencia cardiaca congestiva, o insuficiencia cardiaca, ocurre cuando el corazón no puede bombear suficiente sangre al resto del cuerpo. La pioglitazona (Actos^®^) puede causar insuficiencia cardiaca congestiva o empeorarla si ya existe. Llame a su médico o enfermera si nota repentinamente estos síntomas de insuficiencia cardiaca:

- Un rápido aumento de peso
- Cansancio y debilidad.
- Latidos cardiacos irregulares.
- Hinchazón del abdomen, tobillos o pies.
- Pérdida del apetito o molestias estomacales.
- Falta de aire cuando hace ejercicio o se acuesta.

## Tome una decisión

### ¿Cuánto cuestan estos medicamentos?

El costo para usted depende de varias cosas, por ejemplo:

- El plan de seguro médico que tenga y los medicamentos que éste cubre.
- La cantidad de medicamento que necesite.
- Si toma medicamentos genéricos o de marca comercial.

La mayoría de los medicamentos para la diabetes tipo 2 están cubiertos por los seguros médicos y existen en forma genérica. En el diagrama de la página siguiente se indica el costo promedio para la farmacia de cada medicamento genérico y de marca comercial mencionado en este resumen. Las dosis son similares a las que se utilizaron en los estudios de investigación.

### Precios de mayoreo promedio de medicamentos para la diabetes

Tipo de medicamento | | | Precio por el suministro para 1 mes
Genérico | Marca comercial | Dosis | Genérico | Marca comercial
Biganidas
| | 500 mg una vez al día | $25 | $35
| | 500 mg dos veces al día | $50 | $70
| | 500 mg tres veces al día | $75 | $105
| Glucophage^®^ | 850 mg una vez al día | $40 | $60
| | 850 mg dos veces al día | $80 | $115
Metformina | | 850 mg tres veces al día | $120 | $175
| | 1,000 mg una vez al día | $45 | $70
| | 1,000 mg dos veces al día | $90 | $140
| | 500 mg una vez al día | $25 | $35
| | 1,000 mg una vez al día | $50 | $70
| Glucophage XR^®^ | 1,500 mg una vez al día | $75 | $105
| | 2,000 mg una vez al día | $100 | $140
Sulfonilureas de segunda generación
Glimepirida | Amaryl^®^ | 1 mg una vez al día | $15 | $20
| | 2 mg una vez al día | $25 | $35
| | 4 mg una vez al día | $40 | $60
| | 8 mg una vez al día | $80 | $120
| | 5 mg una vez al día | $15 | $25
| Glucotrol^®^ | 10 mg una vez al día | $25 | $40
| | 10 mg dos veces al día | $50 | $80
Glipizida | | 20 mg dos veces al día | $100 | $160
| Glucotrol XL^®^ | 5 mg una vez al día | $15 | $25
| | 20 una vez al día | $65 | $90
| | 2.5 mg dos veces al día | $40 | $45
| Diabeta^®^ | 5 mg una vez al día | $30 | $40
Gliburida | Micronase^®^ | 5 mg dos veces al día | $60 | $80
| | 1.5 mg una vez al día | $9 | $30
| Glinasa PresTab^®^ | 3 mg una vez al día | $18 | $45
| Glinasa PresTab^®^
| Glinasa PresTab^®^ | 6 mg dos veces al día | $72 | $145
Meglitinidas
Repaglinida | Prandin^®^ | 0.5 mg tres veces al día | ND | $255
| | 1 mg tres veces al día | ND | $255
| | 4 mg tres veces al día | ND | $505
Nateglinida | Starlix^®^ | 60 mg tres veces al día | ND | $195
| | 120 mg tres veces al día | ND | $200
Tiazolidinedionas
| | 15 mg una vez al día | ND | $180
Pioglitazona | Actos^®^ | 30 mg una vez al día | ND | $275
| | 45 mg una vez al día | ND | $300
Inhibidores de la dipeptidil peptidasa-4 (DPP-4)
Sitagliptina | Januvia^®^ | 100 mg una vez al día | ND | $230
Saxagliptina | Onglyza^®^ | 2.5 mg a 5 mg una vez al día | ND | $220
Agonistas del péptido-1 glucagonoide (GLP-1)
Exenatida | Byetta^®^ | Inyección de 5 μg (mcg) dos veces al día | ND | $300
| | Inyección de 10 μg (mcg) dos veces al día | ND | $330
| | Inyección de 0.6 mg una vez al día | ND | $160
Liraglutida | Victoza^®^ | Inyección de 1.2 mg una vez al día | ND | $315
| | Inyección de 1.8 mg una vez al día | ND | $470
Combinaciones
Gliburida/metformina | Glucovance^®^ | 2.5 mg/500 mg dos veces al día | $85 | $90
Gliburida/metformina | Glucovance^®^
Gliburida/metformina | Glucovance^®^ | 5 mg/500 mg dos veces al día | $85 | $90
Metformina/pioglitazona | Actoplus Met^®^ | 500 mg/15 mg dos veces al día | ND | $275
Metformina/pioglitazona | Actoplus Met^®^
Metformina/pioglitazona | Actoplus Met^®^ | 850 mg/15 mg dos veces al día | ND | $275
Metformina/sitagliptina | Janumet^®^ | 500 mg/50 mg dos veces al día | ND | $230
Metformina/sitagliptina | Janumet^®^
Metformina/sitagliptina | Janumet^®^ | 1,000 mg/50 mg dos veces al día | ND | $230
Metformina/saxagliptina | Kombiglyze XR^®^ | 500 mg/5 mg una vez al día | ND | $220
Metformina/saxagliptina | Kombiglyze XR^®^
Metformina/saxagliptina | Kombiglyze XR^®^ | 1,000 mg/2.5 mg una vez al día | ND | $220

Los precios son la mediana del precio federal de los medicamentos genéricos y el precio promedio de mayoreo de los medicamentos de marca comercial. Los precios se redondearon al siguiente $5. Estos precios se obtuvieron de la edición de 2011 del Red Book: Pharmacy’s Fundamental Reference.

XR/XL = efecto prolongado

ND = no está disponible en forma genérica.

### ¿Con qué frecuencia necesitaré tomar estos medicamentos?

- Algunos medicamentos para la diabetes se toman una vez al día. Otros deben tomarse más seguido, o con las comidas.
- Independientemente de los medicamentos que necesite, siga las instrucciones correspondientes de cada uno.
- Siga tomando sus medicamentos hasta que su médico le indique que deje de hacerlo. El no tomar los medicamentos, o tomarlos por poco tiempo, no le ayudará a bajar ni a controlar su nivel de azúcar en la sangre.
- Mídase el azúcar en la sangre todos los días con su monitor de glucosa y acuda a sus pruebas de sangre de A1C en las fechas que el médico se las haya programado.

### ¿Dónde puedo obtener más información sobre la diabetes tipo 2?

Si desea mayor información sobre la diabetes, visite la página web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/diabetes.html.

### Pregunte a su médico

Hable con su médico o personal de atención médica acerca de la información presentada en este resumen de investigaciones.

1. ¿Por qué eligió este medicamento para la diabetes en vez de los otros medicamentos?
2. ¿Este medicamento, me hará sentir mal o diferente, subiré de peso o cambiará mi cuerpo?
3. ¿Cuál es mi número actual de A1C y cuál usted quiere que sea?
4. ¿Cada cuánto debo medirme el azúcar en la sangre y a qué horas?
5. ¿Cómo afectará este medicamento mis actividades diarias, como el trabajo, sueño o la atención que doy a mi familia?

Escriba otras preguntas aquí:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen se obtuvo del informe titulado Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update (Actualización de Medicamentos Orales para Adultos con Diabetes Tipo 2). Fue producida por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Johns Hopkins), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/diabetesmeds.cfm (disponible sólo en inglés).

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) de Houston, TX.