# Medicamentos para tratar la depresión

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si

- El médico u otro profesional de atención médica le ha dicho que usted tiene depresión. Su médico puede referirse a esta condición como trastorno depresivo mayor (MDD, por su sigla en inglés).
- Su médico u otro profesional de atención médica le ha sugerido tomar un tipo específico de medicamento para la depresión llamado “antidepresivo”.
- Usted tiene más de 18 años de edad. Esta información proviene de investigaciones en adultos.

### ¿Qué aprenderé en este resumen?

Este resumen le informará lo que la investigación ha descubierto acerca de los posibles beneficios y los efectos secundarios de los antidepresivos. Esta información le ayudará a hablar con su médico sobre cuál medicamento puede ser mejor para usted.

Los antidepresivos son solamente uno de los tipos de medicamentos que se usan para tratar la depresión. Son los medicamentos más utilizados para tratar esta condición. Su médico puede recetarle medicamentos de otro tipo para tratar la depresión. En este resumen se revisarán solamente las investigaciones relacionadas con los antidepresivos. No se revisarán las investigaciones sobre los tratamientos sin medicamentos. Los estudios de investigación no analizaron tampoco a pacientes con trastorno bipolar, abuso de drogas y alcohol, bulimia nerviosa ni esquizofrenia.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 248 estudios publicados entre enero de 1980 y enero de 2011 acerca de los antidepresivos de segunda generación. Este informe actualiza las investigaciones publicadas originalmente en 2007 e incluye nuevos medicamentos. El informe puede leerse en www.effectivehealthcare.ahrq.gov/secondgenantidep.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la depresión?

La depresión es una enfermedad médica que afecta al cerebro. Es una condición muy común que se presenta en aproximadamente una de cada cinco personas en Estados Unidos. Muchos factores pueden causar depresión, entre ellos los genes (ADN), la química cerebral o factores ambientales como el estrés.

La depresión no es lo mismo que sentirse triste o desanimado de vez en cuando. Las personas con depresión se sienten tristes, cansadas, les falta energía, o se les dificulta disfrutar las actividades cotidianas casi diariamente.

La depresión es un problema serio, pero tratable, que no debe ignorarse.

Muchas personas necesitan que un médico u otro profesional de atención médica les administre algún tipo de tratamiento para la depresión.

No todas las personas con depresión se sienten tristes o desanimadas. Otros síntomas de la depresión son:

- Cambios en los hábitos de sueño, como dormir poco o más de lo habitual.
- Pérdida del interés en las actividades comunes, tales como los pasatiempos preferidos, la convivencia familiar o salidas con los amigos.
- Comer menos o más que antes, ya sea que se tenga o no hambre.
- Fuertes sentimientos de desesperación, desesperanza, o falta de autoestima.
- Dificultad para pensar o concentrarse.
- Sentimientos de culpabilidad excesiva e inapropiada.
- Pensamientos suicidas.

Es posible que usted no advierta algunos de estos síntomas, pero que sí los noten otras personas que viven y trabajan cerca de usted.

## Conozca sus opciones

### ¿Cómo se trata la depresión?

La depresión se trata con medicamentos, terapia de conversación (en la que la persona habla con un profesional capacitado acerca de sus pensamientos y sentimientos; llamada también “psicoterapia” o “consejería”) o con una combinación de ambos métodos.

Este resumen se ocupa solamente de la investigación sobre los medicamentos utilizados para tratar la depresión llamados antidepresivos. Su médico puede enviarlo a consultar con un terapeuta de conversación (psicoterapeuta), además de recetarle medicamentos. Pregunte a su médico los beneficios y riesgos de agregar la psicoterapia a su tratamiento.

Medicamentos antidepresivos^*^

Nombre comercial | ¿Existe genérico? | Nombre del medicamento
Wellbutrin^®^; Wellbutrin SR^®^; Wellbutrin XL^®^ | Sí, en algunas dosis | Bupropión
Celexa^®^ | Sí | Citalopram
Pristiq^®^ | No | Desvenlafaxina
Cymbalta^®^ | No | Duloxetina
Lexapro^®^ | No | Escitalopram
Prozac^®^; Prozac Weekly^®^ | Sí | Fluoxetina
Luvox^®^ | Sí | Fluvoxamina
Remeron^®^; Remeron SolTab^®^ | Sí, en algunas dosis | Mirtazapina
Serzone^®^** | Sí | Nefazodona
Paxil^®^; Paxil CR^®^ | Sí | Paroxetina
Zoloft^®^ | Sí | Sertralina
Desyrel^®^ | Sí | Trazodona
Effexor^®^; Effexor XR^®^ | Sí, en algunas dosis | Venlafaxina

* Para tratar la depresión, su médico puede emplear un medicamento que no esté incluido en esta lista. Los medicamentos de la lista fueron los que se evaluaron en la revisión de la investigación en la que se basa este resumen.

** El nombre comercial Serzone^®^ no está disponible en Estados Unidos. De este medicamento se tiene solamente la forma genérica.

### ¿Qué significan las letras SR, CR, XR y XL después del nombre comercial?

Esas letras en el nombre de un medicamento indican que está en una forma que retrasa o prolonga su liberación en el cuerpo. Eso significa que el medicamento permanece más tiempo dentro del cuerpo, de manera que tal vez pueda tomarlo con menor frecuencia.

- Wellbutrin SR^®^ es un medicamento de liberación sostenida. Este medicamento se toma dos veces al día.
- Paxil CR^®^ es un medicamento de liberación controlada. Este medicamento se toma una vez al día.
- Effexor XR^®^, Wellbutrin XL^®^ y Prozac Weekly^®^ son medicamentos de liberación prolongada. Wellbutrin XL^®^ y Effexor XR^®^ se toman una vez al día. Prozac Weekly^®^ se toma una vez a la semana.

### ¿Cómo funcionan estos medicamentos?

Los medicamentos antidepresivos ayudan a mejorar la forma en que el cerebro utiliza ciertas sustancias químicas que controlan el estado de ánimo o el estrés.

### ¿Qué dicen las investigaciones respecto a qué tanto ayudan estos medicamentos a las personas que padecen depresión?

- Todos los medicamentos antidepresivos tienen casi la misma eficacia para aliviar los síntomas de la depresión y mejorar la calidad de vida de las personas que la padecen.
- Todos los medicamentos antidepresivos funcionan casi igual de bien para evitar que los síntomas de la depresión regresen.

¿Qué tan bien funcionan estos medicamentos?

Aunque todos los medicamentos antidepresivos funcionan igualmente bien, es importante recordar que algunas personas no se sentirán mejor con el primer medicamento que tomen. Es posible que deban probar varios medicamentos antes de encontrar uno que les funcione. Otros tal vez descubran que, aunque el medicamento les ayudó por un tiempo, los síntomas regresaron. Para que el medicamento funcione, es importante seguir cuidadosamente las indicaciones médicas para su uso.

Solamente tres de cada cinco personas verán que su depresión mejora la primera vez que empiecen a tomar un medicamento antidepresivo.

### ¿Qué descubrieron las investigaciones sobre antidepresivos específicos?

Las investigaciones han encontrado cierta información específica acerca de los beneficios de algunos medicamentos:

- Las personas que tomaron mirtazapina (Remeron^®^) empezaron a sentirse mejor con más rápidez que cuando tomaron otros antidepresivos. Remeron^®^ tardó entre 1 y 2 semanas en empezar a hacer efecto. Los otros antidepresivos mostraron su funcionamiento cerca de las 4 semanas.
- Prozac Weekly^®^ y Paxil CR^®^ son igual de eficaces que Prozac^®^ y Paxil^®^ regulares.
- Pocas personas dejaron de tomar venlafaxina (Effexor^®^, Effexor XR^®^) por falta de eficacia en comparación con otros antidepresivos. Las personas que dejaron de tomar venlafaxina lo hicieron por causa de efectos secundarios como náusea y vómito.

### ¿Pueden los antidepresivos aliviar otros problemas relacionados con la depresión?

- Ansiedad. Las personas que padecían depresión observaron mejoría con su ansiedad. Todos los medicamentos estudiados mostraron casi el mismo grado de mejoría.
- Dolor. Tanto la paroxetina (Paxil^®^) como la duloxetina (Cymbalta^®^) ayudaron casi igual a pacientes con depresión y con dolor crónico.
- Insomnio (cuando uno no puede conciliar o mantener el sueño). La fluoxetina (Prozac^®^), la mirtazapina (Remeron^®^), la paroxetina (Paxil^®^) y la sertralina (Zoloft^®^) ayudaron casi igual a las personas con insomnio, pero no existe suficiente investigación para poder afirmarlo con certeza.

### ¿Cuáles son los efectos secundarios de los antidepresivos?

El número de personas que tienen algún efecto secundario por el uso de un antidepresivo es casi el mismo con todos los medicamentos de este tipo. Sin embargo, los efectos secundarios de cada medicamento pueden ser diferentes y algunos tienden a causar determinados efectos secundarios con mayor frecuencia que otros.

Según datos de la Food and Drug Administration de Estados Unidos (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés), los efectos secundarios más frecuentes de los antidepresivos de que trata este resumen son:

- Náusea y vómito
- Aumento de peso
- Diarrea
- Sueño
- Problemas sexuales

Otros efectos secundarios más graves, aunque mucho menos frecuentes, que señala la FDA en relación con los antidepresivos analizados en este resumen pueden ser: convulsiones, problemas del corazón, desequilibrio de la sal (sodio) en la sangre, daño al hígado, pensamientos suicidas o síndrome de serotonina (reacción que puede causar la muerte debido a que el cuerpo produce esta sustancia en exceso). El síndrome de serotonina puede causar temblores, diarrea, fiebre, convulsiones y entumecimiento o rigidez muscular.

Si usted tiene pensamientos suicidas u otros efectos secundarios graves, como convulsiones o problemas del corazón mientras toma medicamentos antidepresivos, avise inmediatamente a su médico.

Obtenga ayuda de la National Suicide Prevention Lifeline (Línea Nacional para la Prevención del Suicidio) llamando al teléfono 1-800-273-TALK (8255) o en la página web www.suicidepreventionlifeline.org.

### Medicamentos más propensos a causar ciertos efectos secundarios

Aunque todos los antidepresivos pueden causar efectos secundarios, algunos tienden más que otros a causar ciertos efectos secundarios.

Efecto secundario | Medicamentos más propensos a causar este efecto secundario
Náusea o vómito | - Venlafaxina (Effexor^®^, Effexor XR^®^); - Paroxetina (Paxil^®^)
Aumento de peso | - Mirtazapina (Remeron^®^, Remeron SolTab^®^); - Entre 2 y 7 libras en 6 a 8 semanas
Diarrea | - Sertralina (Zoloft^®^)
Sueño | - Trazodona (Desyrel^®^)
Problemas sexuales (como reducción del impulso sexual o dificultad para lograr la erección) | - Paroxetina (Paxil^®^, Paxil CR^®^); - El escitalopram (Lexapro^®^), la fluoxetina (Prozac^®^, Prozac Weekly^®^), la paroxetina (Paxil^®^, Paxil CR^®^) o la sertralina (Zoloft^®^) tuvieron más efectos secundarios sexuales que el bupropión (Wellbutrin^®^, Wellbutrin SR^®^, Wellbutrin XL^®^)

### ¿Qué sucede si dejo de tomar mi antidepresivo?

- Algunas personas tienen síntomas cuando dejan de tomar ciertos medicamentos antidepresivos. Se les llama “síntomas de abstinencia” o withdrawal symptoms, en inglés. Los síntomas de abstinencia consisten en dolor de cabeza, mareo, desmayo, náusea y ansiedad. Nunca deje de tomar su medicamento sin antes preguntar al médico.
  - Más personas tuvieron estos síntomas después de que dejaron de tomar la paroxetina (Paxil^®^, Paxil CR^®^) y la venlafaxina (Effexor^®^, Effexor XR^®^).
  - Menos personas tuvieron síntomas de abstinencia después de dejar de tomar fluoxetina (Prozac^®^, Prozac Weekly^®^).

## Tome una decisión

### ¿En qué cosas debo pensar?

Usted y su médico pueden decidir si vale la pena tomarse el riesgo de tener posibles efectos secundarios por usar un cierto medicamento. Hay varias cosas que probablemente quiera usted considerar y comentar con su médico:

- Los tipos de síntomas de depresión que usted tiene y qué tanto le molestan.
- El efecto que pueda tener en su vida, su trabajo y sus relaciones el hecho de no tomar el medicamento antidepresivo.
- Ciertos efectos secundarios y cómo pueden afectar su vida diaria o su trabajo.
- Qué forma del medicamento (de liberación inmediata, sostenida [SR], controlada [CR] o prolongada [ER]) sería el mejor para usted.
- Otros problemas de salud que pueda estar enfrentando y cómo estos medicamentos interactúan con otros que esté usted tomando.
- Si algún tipo de psicoterapia o terapia de conversación sería útil mientras toma usted el medicamento.
- El costo del medicamento.

Es posible que tenga que probar varios medicamentos antidepresivos antes de encontrar aquel que alivie sus síntomas y tenga efectos secundarios que pueda controlar. Es importante que hable con su médico acerca de:

- El tiempo que deberá usar un medicamento para saber si le ayuda o si le causa efectos secundarios.
- Cuándo necesita informarle al médico que el medicamento causó un efecto secundario.
- Qué deben hacer sus familiares y amigos para apoyarlo mientras se está tratando por la depresión.

### ¿Cuáles son los costos de estos medicamentos?

En el diagrama siguiente se muestra el precio de mayoreo (el costo para la farmacia) de cada uno de los antidepresivos que se analizan en este resumen. El costo real para usted puede ser diferente, dependiendo de:

- El copago que tenga que hacer del seguro médico.
- La dosis (cantidad) que necesite tomar.
- Si existe una forma genérica del medicamento.

Precios de mayoreo de los antidepresivos con receta

Nombre comercial | Dosis disponibles | Costo de la marca por mes | Nombre genérico | Precio del genérico por mes
Celexa^®^ | 10 mg | $126 | Citalopram | $72
Celexa^®^ | 20 mg | $131 | Citalopram | $75
Celexa^®^ | 40 mg | $137 | Citalopram | $78
Cymbalta^®^ | 60 mg | $150 | Duloxetina | ND
Desyrel^®^ | 50 mg | $60 | Trazodona | $5
Desyrel^®^ | 100 mg | $113 | Trazodona | $6
Effexor^®^ | 25 mg | $54 | Venlafaxina | ND (todas las dosis)
Effexor^®^ | 50 mg | $69 | Venlafaxina | ND (todas las dosis)
Effexor^®^ | 75 mg | $75 | Venlafaxina | ND (todas las dosis)
Effexor^®^ | 100 mg | $81 | Venlafaxina | ND (todas las dosis)
Effexor XR^®^ | 37.5 mg | $171 | ND | ND
Lexapro^®^ | 5 mg | $138 | Escitalopram | ND (todas las dosis)
Lexapro^®^ | 10 mg | $146 | Escitalopram | ND (todas las dosis)
Lexapro^®^ | 20 mg | $152 | Escitalopram | ND (todas las dosis)
Luvox^®^ | 25 mg | $89 | Fluvoxamina | $69
Luvox^®^ | 50 mg | $100 | Fluvoxamina | $78
Luvox^®^ | 100 mg | $102 | Fluvoxamina | $79
Paxil^®^ | 10 mg | $133 | Paroxetina | $79
Paxil^®^ | 20 mg | $139 | Paroxetina | $80
Paxil^®^ | 30 mg | $143 | Paroxetina | $85
Paxil^®^ | 40 mg | $151 | Paroxetina | $90
Paxil CR^®^ | 12.5 mg | $137 | Paroxetina | $109
Paxil CR^®^ | 25 mg | $143 | Paroxetina | $114
Paxil CR^®^ | 37.5 mg | $147 | Paroxetina | $117
Pristiq^®^ | 50 mg | $163 | Desvenlafaxina | ND (todas las dosis)
Pristiq^®^ | 100 mg | $163 | Desvenlafaxina | ND (todas las dosis)
Prozac^®^ | 10 mg | $90 | Fluoxetina | $78
Prozac^®^ | 20 mg | $120 | Fluoxetina | $80
Prozac Weekly^®^ | 40 mg | $165 | | $160
Remeron^®^ | 25 mg | $138 | Mirtazapina | $82
Remeron^®^ | 50 mg | $142 | Mirtazapina | $84
Remeron^®^ | 100 mg | $145 | Mirtazapina | $86
Remeron^®^ SolTab^®^ | 15 mg | $110 | Mirtazapina | ND (todas las dosis)
Remeron^®^ SolTab^®^ | 30 mg | $113 | Mirtazapina | ND (todas las dosis)
Remeron^®^ SolTab^®^ | 45 mg | $120 | Mirtazapina | ND (todas las dosis)
Serzone^®^** | 50 mg | ND (todas las dosis) | Nefazodona | $54
Serzone^®^** | 100 mg | ND (todas las dosis) | Nefazodona | $56
Serzone^®^** | 150 mg | ND (todas las dosis) | Nefazodona | $57
Serzone^®^** | 200 mg | ND (todas las dosis) | Nefazodona | $58
Serzone^®^** | 250 mg | ND (todas las dosis) | Nefazodona | $59
Wellbutrin^®^ | 75 mg | $80 | Bupropión | $22
Wellbutrin^®^ | 100 mg | $107 | Bupropión | $51
Wellbutrin SR^®^ | 100 mg | $123 | Bupropión | ND
Wellbutrin SR^®^ | 150 mg | $132 | Bupropión | $58
Wellbutrin SR^®^ | 200 mg | $246 | Bupropión | $115
Wellbutrin XL^®^ | 150 mg | $248 | Bupropión | ND
Wellbutrin XL^®^ | 300 mg | $327 | Bupropión | ND
Zoloft^®^ | 25 mg | $153 | Sertralina | ND (todas las dosis)
Zoloft^®^ | 50 mg | $153 | Sertralina | ND (todas las dosis)
Zoloft^®^ | 100 mg | $153 | Sertralina | ND (todas las dosis)

ND = no disponible

SR, XL, CR y XR se refieren todos a fórmulas de liberación prolongada.

* Los precios son el promedio de los precios de mayoreo reproducidos de RED BOOK Online^®^. Los precios del medicamento genérico son el promedio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

** El nombre comercial Serzone^®^ no está disponible en Estados Unidos. De este medicamento se tiene solamente la forma genérica.

### Pregunte a su médico

- ¿Qué medicamento antidepresivo considera que sería el mejor para tratar mi depresión?
- ¿Qué efectos secundarios debo buscar y en qué momento debo avisarle de ellos?
- ¿Cómo sabremos si ya es momento de probar con una cantidad diferente del medicamento o con un medicamento distinto?
- ¿Afectará la eficacia del antidepresivo alguno de mis otros problemas de salud o medicamentos?
- ¿Debo también consultar a un terapeuta de conversación (psicoterapeuta) o consejero?

#### Otras preguntas para su médico

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

#### Anote aquí las respuestas

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review (Antidepresivos de segunda generación en el tratamiento farmacológico de la depresión del adulto: actualización de la revisión de eficacia comparada de 2007), publicado en diciembre de 2011.

El informe fue producido por RTI International–University of North Carolina Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Carolina del Norte–RTI International) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/secondgenantidep.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con depresión.

Esta guía fue traducida de la publicación en inglés titulada Medicines for Treating Depression: A Review of the Research for Adults.