# Medicamentos antidepresivos

Guía para adultos con depresión

## Hechos resumidos

- Los antidepresivos incluidos en esta guía sirven para tratar la depresión. La mayoría de las personas encuentran uno que los hace sentir mejor.
- Seis de cada 10 personas mejoran con el primer antidepresivo que prueban. El resto necesita probar otros para poder encontrar el antidepresivo adecuado.
- La mayoría de las personas que toman antidepresivos presentan por lo menos un efecto secundario.
- Los efectos secundarios más frecuentes son estreñimiento, sueño durante el día, diarrea, mareo, boca seca, dolor de cabeza, náuseas, problemas sexuales, temblores, problemas para dormir, y aumento de peso.

## ¿Qué cubre esta guía?

Esta guía le ayudará a colaborar con su médico o enfermera en la elección de un medicamento antidepresivo. Se tratan los siguientes temas:

- Medicamentos comunes en adultos con depresión.
- Efectos secundarios.
- Costo.

La información proviene de una revisión de investigaciones financiada por el gobierno acerca de medicamentos de uso común para el tratamiento de la depresión en adultos. En la página 8 se presenta una lista de estos antidepresivos.

## ¿Qué no cubre esta guía?

La guía no trata los siguientes temas:

- Tratamiento de la depresión en niños o adolescentes.
- Depresión posparto o “melancolía de la maternidad”, lo que en inglés se conoce como baby blues.
- La depresión que forma parte de otros problemas de salud mental, como el trastorno bipolar (antes llamado trastorno maníaco-depresivo).
- Medicamentos antidepresivos más antiguos, como la amitriptilina (Elavil®) y la fenelzina (Nardil®).
- Otras formas de tratamiento de la depresión, incluyendo la psicoterapia, terapia con luz intensa, y suplementos herbarios, como la hierba de San Juan.

## ¿Cuáles son los signos o síntomas comunes de la depresión?

La depresión es una tristeza profunda que no desaparece. Puede expresarse también por pérdida del interés en hacer cosas y actividades normalmente placenteras. Los síntomas más comunes son:

- Sensación de tristeza, ansiedad, o “vacío” que dura más de 2 semanas.
- Problemas para dormir.
- Cambios del apetito, ya sea menor apetito y reducción de peso, o mayor consumo de alimentos y aumento de peso.
- Pérdida del interés en hacer cosas que solía disfrutar, incluso el sexo.
- Sensación de agitación e irritabilidad.
- Síntomas físicos persistentes que no disminuyen con el tratamiento (como dolor crónico).
- Dificultad para prestar atención, tomar decisiones, o recordar.
- Sentirse cansado todo el tiempo o como si no tuviera energía.
- Sentirse culpable, desesperado, o insignificante.
- Ideas recurrentes de suicidio o de muerte.

La depresión es una condición tratable. Usted puede mejorar. Los tratamientos más frecuentes contra la depresión consisten en medicamentos antidepresivos, apoyo psicológico, o una combinación de ambos.

## ¿Qué debo decirle a mi médico o enfermera?

- Dígale a su médico o enfermera cómo se siente.
- Describa cualquier síntoma que tenga, como falta de apetito, cansancio persistente, problemas para conciliar o mantener el sueño, falta de interés en el sexo, o sentimientos de extrema preocupación.
- Dígales qué síntomas le molestan más.
- Cuénteles de cualquier otra condición física o mental que tenga.
- Lleve a su consulta una lista de todos sus medicamentos, sean de farmacia sin receta o con receta. No olvide informarles si está tomando productos herbarios, como la hierba de San Juan, o cualquier otro suplemento.
- Infórmele a su médico o enfermera si ha tomado algún antidepresivo antes y qué resultados obtuvo.

## Beneficios de los antidepresivos

### ¿Me ayudará el medicamento?

- La mayoría de las personas encuentran un antidepresivo efectivo.
- Seis de cada 10 personas se sienten mejor con el primer antidepresivo que prueban. El resto necesitará probar diferentes antidepresivos hasta encontrar el adecuado.

### ¿Cuánto tiempo tardaré en sentirme mejor?

- La mayoría de las personas necesita tomar regularmente un antidepresivo por un mínimo de 6 semanas, para empezar a obtener el efecto completo.
- Si aún no se siente mejor, su médico o enfermera pueden recetarle un antidepresivo diferente o añadir otro.
- La mayoría de las personas debe seguir tomando estos medicamentos de 6 a 9 meses. Algunas personas necesitan tomarlos por más tiempo.

## Explicación de los efectos secundarios

Todos los antidepresivos que se mencionan en esta guía pueden causar efectos secundarios. Si estos efectos resultan problemáticos, su médico o enfermera le ayudarán a encontrar otro medicamento.

- La mayoría de las personas que toman estos medicamentos presentan por lo menos un efecto secundario. Es difícil saber de antemano qué medicamento tendrá cierto efecto secundario en una persona determinada.
- Los efectos secundarios más frecuentes son estreñimiento, sueño durante el día, diarrea, mareo, boca seca, dolor de cabeza, náuseas, problemas sexuales, temblores, problemas para dormir, y aumento de peso.
- Muchos efectos secundarios desaparecen después de algunas semanas. Sin embargo, algunos se resuelven solamente después de suspender el medicamento.

## Investigaciones que compran lose efectos secundarios

Algunos de los medicamentos incluidos en esta guía se han comparado entre sí en estudios de investigación. Ésta es la información que han aportado esos estudios:

### Mayor probabilidad de aumento de peso

- Suben más de peso las personas que toman mirtazapina (Remeron®) que las que toman:
  - -citalopram (Celexa®)
  - -fluoxetina (Prozac®)
  - -paroxetina (Paxil®)
  - -sertralina (Zoloft®)

El aumento de peso con la mirtazapina (Remeron®) es de 2 a 7 libras (0.9 a 3 kg). Algunas personas pueden aumentar mucho más.

- Aumentan más de peso las personas que usan paroxetina (Paxil®) que las que toman:
  - -fluoxetina (Prozac®)
  - -sertralina (Zoloft®)

El aumento de peso medio con la paroxetina (Paxil®) en una persona que pesa 150 libras (68 kg) es de 5 libras (2.25 kg). Algunas personas pueden aumentar mucho más.

### Mayor probabilidad de reducción de peso

- Las personas que toman bupropión (Wellbutrin®) bajan poco de peso, entre 2 y 3 libras (0.9 y 1.8 kg).

### Menor probabilidad de problemas sexuales

- Menos personas que toman bupropión (Wellbutrin®) tienen problemas sexuales (pérdida del deseo sexual o de la capacidad de llegar al orgasmo) que las que toman:
  - -fluoxetina (Prozac®)
  - -paroxetina (Paxil®)
  - -sertralina (Zoloft®)

### Mayor probabilidad de problemas sexuales

- Más personas que toman paroxetina (Paxil®) tienen problemas sexuales que las que toman:
  - -fluoxetina (Prozac®)
  - -fluvoxamina
  - -nefazodona
  - -sertralina (Zoloft®)

### Mayor probabilidad de náusea y vómito

- Más personas (10 por ciento más) presentan náusea y vómito con venlafaxina (Effexor®) que con:
  - -citalopram (Celexa®)
  - -escitalopram (Lexapro®)
  - -fluoxetina (Prozac®)
  - -fluvoxamina
  - -paroxetina (Paxil®)
  - -sertralina (Zoloft®)

### Mayor probabilidad de diarrea

- Más personas (8 por ciento más) tienen diarrea con sertralina (Zoloft®) que con:
  - -bupropión (Wellbutrin®)
  - -citalopram (Celexa®)
  - -fluoxetina (Prozac®)
  - -fluvoxamina
  - -paroxetina (Paxil®)
  - -mirtazapina (Remeron®)
  - -nefazodona
  - -venlafaxina (Effexor®)

## No suspenda su medicamento repentinamente

Nunca deje de tomar repentinamente un medicamento antidepresivo. Si suspende del todo su medicamento, puede sentirse enfermo, como si tuviera gripe. Puede tener dolores de cabeza, mareos, y náuseas. Siga las indicaciones de su médico o enfermera para reducir poco a poco su dosis antes de suspender el medicamento.

- Entre los antidepresivos incluidos en esta guía, la paroxetina (Paxil®) y la venlafaxina (Effexor®) tienden más a causar estos síntomas parecidos a los de la gripe cuando se interrumpen repentinamente.
- La fluoxetina (Prozac®) tiende menos que los otros a causar estos síntomas.

## Riesgos importantes

### Síndrome de la serotonina

El síndrome de la serotonina es una reacción rara a los medicamentos, pero importante. La serotonina es una sustancia química que producen las células nerviosas. Los antidepresivos incluidos en esta guía aumentan la cantidad de serotonina en el cerebro. Este efecto es bueno hasta cierto punto. Sin embargo, un exceso de esta sustancia puede causar el síndrome de la serotonina. Entre los síntomas comunes se encuentran confusión, alucinaciones, pérdida de coordinación, fiebre, latido rápido del corazón, y vómito.

#### ¿Cuál es la causa?

El síndrome de la serotonina ocurre con mayor frecuencia cuando se toman al mismo tiempo dos medicamentos que aumentan esta sustancia en el cerebro. Otros medicamentos que aumentan la serotonina son:

- Los triptanos (Amerge®, Imitrex®), medicamentos que se utilizan para tratar la migraña.
- El suplemento L-triptófano.
- Productos herbarios como la hierba de San Juan.
- Medicamentos de farmacia sin receta contra la tos, como el dextrometorfano.
- Medicamentos contra el dolor que se venden con receta, como la meperidina (Demerol®).

#### ¿Cómo puede evitarlo?

Consulte a su médico o farmacéutico antes de tomar otros medicamentos, suplementos, o productos herbarios de venta en farmacias sin receta o con receta médica.

### Suicidio

Los antidepresivos pueden aumentar el riesgo de suicidio en personas menores de 25 años. Independientemente de su edad, si su depresión empeora o le viene la idea de hacerse daño, por favor hable con su médico.

## ¿Qué aspectos no se conocen todavía?

- No se sabe mucho sobre el uso a largo plazo de estos medicamentos, porque los estudios de investigación suelen durar solamente entre 3 meses y 1 año.
- No se sabe si algún antidepresivo es más efectivo en las mujeres que en los hombres o en personas de determinadas razas.
- No se sabe si alguno de estos antidepresivos es mejor que los otros para corregir los síntomas que a veces acompañan la depresión, como los problemas para dormir y el dolor.
- No se sabe si alguno de estos antidepresivos aumente más que los otros el riesgo de suicidio.

## Cómo utilizar la información de esta guía

Al hablar sobre los antidepresivos con su médico o enfermera, piense en lo siguiente:

### ¿Cuáles son los efectos secundarios más importantes para usted?

- ¿Le preocupan más los problemas sexuales, como la pérdida del deseo sexual o de la capacidad de llegar al orgasmo?
  Puede consultar a su médico o enfermera sobre el bupropión (Wellbutrin®).
- ¿Le preocupa el aumento de peso?
  Puede consultar a su médico o enfermera sobre el uso de bupropión (Wellbutrin®). Tal vez prefiera evitar la paroxetina (Paxil®) y la mirtazapina (Remeron®).
- ¿Le preocupa más la náusea y el vómito?
  Éstos son los efectos secundarios que con mayor frecuencia llevan a la persona a dejar de tomar su medicamento antidepresivo durante los primeros 30 días.
  Si su medicamento le causa náusea, vómito, o algún otro efecto secundario, avísele a su médico o enfermera. Puede haber una solución.

### ¿Con qué frecuencia necesitará tomar el medicamento?

Algunos antidepresivos se toman una vez al día. Otros deben tomarse más a menudo. En la página 8 se presenta una lista de antidepresivos y la frecuencia con que deben tomarse.

### ¿Es importante el costo?

Use el cuadro abajo para comparar los precios de distintos medicamentos. Si su seguro médico cubre medicamentos con receta, pregunte cuál sería el costo para usted.

DOSIS Y COSTOS DE LOS ANTIDEPRESIVOS

Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Costo para provisión de 1 mes^3^
Nombre genérico^1^ | Nombre de la marca | Dosis^2^ | Genérico | Marca
Bupropión | Wellbutrin® | 75 mg tres veces al día | $65 | $160
Bupropión | Wellbutrin® | 150 mg tres veces al día | $175 | $210
Bupropión
Bupropión | Wellbutrin SR® | 150 mg una vez al día | $60 | $85
Bupropión | Wellbutrin SR® | 150 mg dos veces al día | $115 | $175
Bupropión | Wellbutrin SR® | 200 mg dos veces al día | $230 | $320
Bupropión
Bupropión | Wellbutrin XL® | 150 mg una vez al día | No existe genérico | $125
Bupropión | Wellbutrin XL® | 300 mg una vez al día | No existe genérico | $165
Bupropión | Wellbutrin XL® | 450 mg una vez al día | No existe genérico | $290
Citalopram | Celexa® | 10 mg una vez al día | $75 | $90
Citalopram | Celexa® | 20 mg una vez al día | $75 | $95
Citalopram | Celexa® | 40 mg una vez al día | $80 | $100
Citalopram | Celexa® | 60 mg una vez al día | $155 | $195
Duloxetina | Cymbalta® | 20 mg dos veces al día | No existe genérico | $215
Duloxetina | Cymbalta® | 30 mg dos veces al día | No existe genérico | $240
Duloxetina | Cymbalta® | 60 mg dos veces al día | No existe genérico | $240
Escitalopram | Lexapro® | 10 mg una vez al día | No existe genérico | $80
Escitalopram | Lexapro® | 20 mg una vez al día | No existe genérico | $85
Fluoxetina | Prozac® | 10 mg una vez al día | $80 | $145
Fluoxetina | Prozac® | 20 mg una vez al día | $80 | $150
Fluoxetina | Prozac® | 40 mg una vez al día | $160 | $295
Fluoxetina | Prozac® | 40 mg dos veces al día | $320 | $595
Fluoxetina
Fluoxetina | Prozac Weekly® | 90 mg una vez por semana | No existe genérico | $110
Fluvoxamina | Existe sólo el genérico | 50 mg una vez al día | $75 | Existe sólo el genérico
Fluvoxamina | Existe sólo el genérico | 100 mg una vez al día | $80 | Existe sólo el genérico
Fluvoxamina | Existe sólo el genérico | 150 mg una vez al día | $160 | Existe sólo el genérico
Mirtazapina | Remeron® | 15 mg una vez al día | $80 | $105
Mirtazapina | Remeron® | 30 mg una vez al día | $85 | $110
Mirtazapina | Remeron® | 45 mg una vez al día | $85 | $110
Nefazodona | Existe sólo el genérico | 50 mg dos veces al día | $90 | Existe sólo el genérico
Nefazodona | Existe sólo el genérico | 100 mg dos veces al día | $90 | Existe sólo el genérico
Nefazodona | Existe sólo el genérico | 300 mg dos veces al día | $200 | Existe sólo el genérico
Paroxetina | Paxil® | 10 mg una vez al día | $80 | $95
Paroxetina | Paxil® | 20 mg una vez al día | $80 | $100
Paroxetina | Paxil® | 40 mg una vez al día | $85 | $110
Paroxetina | Paxil® | 60 mg una vez al día | $165 | $210
Sertralina | Zoloft® | 50 mg una vez al día | $85 | $90
Sertralina | Zoloft® | 100 mg una vez al día | $85 | $90
Sertralina | Zoloft® | 200 mg una vez al día | $170 | $180
Trazodona | Desyrel® | 50 mg una vez al día | $15 | $70
Trazodona | Desyrel® | 100 mg tres veces al día | $65 | $355
Trazodona | Desyrel® | 150 mg tres veces al día | $130 | $305
Venlafaxina | Effexor® | 37.5 mg dos veces al día | No existe genérico | $135
Venlafaxina | Effexor® | 50 mg dos veces al día | No existe genérico | $140
Venlafaxina | Effexor® | 75 mg tres veces al día | No existe genérico | $220
Venlafaxina
Venlafaxina | Effexor XR® | 75 mg una vez al día | No existe genérico | $110
Venlafaxina | Effexor XR® | 150 mg una vez al día | No existe genérico | $120
Venlafaxina | Effexor XR® | 225 mg una vez al día | No existe genérico | $230

1 Estos medicamentos se incluyeron en los estudios de investigación.

2 Dosis similares a las utilizadas en los estudios de investigación.

3 El costo promedio al por mayor proviene del Drug Topics Redbook, 2007.

SR = liberación sostenida, XL/XR = liberación extendida.

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía y materiales sobre la elección de tratamientos y medicamentos para otras condiciones médicas, visite esta página Web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm (http://effectivehealthcare.ahrq.gov/index.cfm/guides-for-patients-and-consumers/informacion-en-espanol/)

Para obtener una copia gratuita, llame a: AHRQ Publications Clearinghouse, (800) 358-9295

Pida la publicación de AHRQ número: 07(09)-EHC007-B

Si desea más información sobre la depresión, visite la página Web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/depression.html

Si desea información sobre servicios y recursos de salud mental en su estado, pruebe el Localizador de servicios de salud mental de esta página Web: mentalhealth.samhsa.gov/databases/

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 293 informes de investigación. La revisión se titula Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression – 2007 (Comparación de la efectividad de antidepresivos de segunda generación para el tratamiento farmacológico de la depresión en adultos – 2007), y fue escrita por el RTI International-University of North Carolina Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Internacional RTI de Carolina del Norte).

## Related Content

Research Review

Clinician Guide

Consumer Guide