# Medicamentos para la enfermedad renal crónica en fase inicial

Revisión de las investigaciones para adultos con enfermedad renal y diabetes o presión arterial alta

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico le ha dicho que padece de enfermedad renal crónica (ERC) en fase inicial. Eso significa que sus análisis de sangre u orina muestran signos de daño en los riñones. También significa que sus riñones no están llevando a cabo su función de limpiar la sangre de forma debida.

#### O bien

- Su médico le ha dicho que usted tiene ERC en fase inicial y una o más condiciones que aumentan el riesgo de que tenga problemas con los riñones. Algunas de estas condiciones son: diabetes, presión arterial alta, colesterol alto o enfermedades del corazón o de los vasos sanguíneos. Usted desea saber lo que dicen las investigaciones sobre cómo proteger sus riñones de un daño mayor.

### No, esta información no es apropiada para usted si

- Tiene menos de 18 años de edad. Esta información proviene de investigación realizada en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen le informará sobre los medicamentos para las personas con enfermedad renal crónica en fase inicial y diabetes, presión arterial alta, colesterol alto o enfermedades del corazón o los vasos sanguíneos. Le explicará lo que dicen las investigaciones acerca de los beneficios y posibles efectos secundarios de estos medicamentos. Puede ayudarle a hablar con su médico y determinar si alguno de estos medicamentos es apropiado para usted.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 110 estudios acerca de los tratamientos para personas con enfermedad renal crónica publicados entre enero de 1985 y enero de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/ckd.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la enfermedad renal crónica?

La enfermedad renal crónica (ERC) es una condición que causa daño permanente a los riñones e impide que éstos funcionen correctamente.

Sus riñones son órganos importantes que tienen muchas funciones. La función principal de los riñones consiste en eliminar desechos y excedentes de líquido y sal del cuerpo. Para lograrlo, extraen los desechos de la sangre y producen orina. Los riñones también le ayudan a controlar la presión arterial y el equilibrio de las sustancias químicas en su cuerpo. Es importante mantener nuestros riñones sanos.

Si les ocurre algún daño a sus riñones, ya no podrán cumplir su función debidamente. Una persona padece de ERC si su función renal (la eficacia con que trabajan los riñones) se reduce durante 3 meses consecutivos o más. Con el tiempo, si no se trata, la ERC puede empeorar y ocasionar que sus riñones dejen de funcionar. Aproximadamente 11 de cada 100 adultos en Estados Unidos padecen de ERC.

### ¿Por qué es peligrosa la ERC?

Cuando los riñones no funcionan correctamente, dejan desechos en la sangre. Los desechos pueden acumularse y enfermarlo. Esto puede causarle problemas del corazón y aumentar su riesgo de pérdida ósea, fracturas, anemia (disminución de los glóbulos rojos, que transportan el oxígeno en el cuerpo), insuficiencia renal total y otros problemas graves. También puede causar la muerte.

### ¿Cómo sé si tengo ERC?

Su médico puede analizar su sangre u orina para saber qué tan bien están funcionando sus riñones. Estas pruebas miden la cantidad de desechos en la sangre o de proteína en la orina. Una cantidad alta de desechos en la sangre o de proteína en la orina puede indicar que hay daño en los riñones.

### ¿Qué es la ERC en fase inicial?

Su médico puede decirle que tiene ERC “en fase inicial” si sus riñones sólo han dejado de funcionar un poco. El objetivo del tratamiento para la ERC en fase inicial es retardar el daño a los riñones.

Si sus riñones ya no funcionan debidamente para eliminar los desechos, es posible que tenga ERC “en fase terminal”. Con el tiempo, las personas con ERC en fase terminal necesitarán la diálisis (tratamiento que usa una máquina para eliminar los desechos de la sangre) o un trasplante renal.

En la mayoría de las personas, la función renal se va deteriorando lentamente conforme aumenta la edad. Los riñones que presentan daño pueden dejar de funcionar con más rápidez.

### ¿Cuáles son los síntomas de ERC?

Las personas con ERC en fase inicial muy rara vez tienen algún síntoma. Como a menudo no hay síntomas en las primeras fases, muchas personas no saben que tienen ERC hasta que su función renal disminuye demasiado.

Algunos síntomas de la ERC en fase terminal pueden ser: pérdida del apetito, cambios en el peso, náuseas e hinchazón de tobillos y pies. La ERC en fase terminal puede también hacer que se sienta enfermo, cansado y producir picazón o sequedad en la piel.

### ¿Qué causa la ERC?

Las causas más comunes de ERC son: presión arterial alta y azúcar en la sangre alta por diabetes. La ERC también se presenta en personas con el colesterol alto o que tienen enfermedades del corazón y de los vasos sanguíneos.

## Información sobre sus opciones

### ¿Qué medicamentos pueden ayudar?

Hay cuatro tipos de medicamento que pueden ayudar a las personas con ERC:

- Inhibidores de la enzima convertidora de angiotensina (IECA)
- Bloqueadores o antagonistas de los receptores de la angiotensina II (BRA)
- Bloqueadores beta
- Estatinas

Tanto los IECA como los BRA y los bloqueadores beta son tipos de medicamentos que se usan para reducir la presión arterial, pero funcionan de maneras distintas. Los IECA y los BRA puede retardar el daño al riñón incluso en las personas que no tienen presión arterial alta. Las estatinas son un tipo de medicamento que se usa para reducir el colesterol.

IECA
Nombre comercial * | Nombre genérico
Accupril^®^ | Quinapril
Aceon^®^ | Perindopril
Altace^®^ | Ramipril
Capoten^®^ | Captopril
Lotensin^®^ | Benazepril
Mavik^®^ | Trandolapril
Monopril^®^ | Fosinopril
Prinivil^®^ o Zestril^®^ | Lisinopril
Univasc^®^ | Moexipril
Vasotec^®^ | Enalapril

* Todos estos IECA están disponibles en forma genérica.

BRA
Nombre comercial * | Nombre genérico
Atacand^®^ | Candesartán
Avapro^®^ | Irbesartán
Benicar^®^ | Olmesartán
Cozaar^®^* | Losartán
Diovan^®^ | Valsartán
Micardis^®^ | Telmisartán
Teveten^®^ | Eprosartán

* El único BRA disponible en forma genérica es Cozaar^®^.

Bloqueadores beta
Nombre comercial * | Nombre genérico
Bystolic^®^ | Nebivolol
Coreg^®^* | Carvedilol
Corgard^®^* | Nadolol
Inderal^®^ o Inderal LA^®^* | Propranolol
Levatol^®^ | Penbutolol
Lopressor^®^ | Metoprolol
Sectral^®^* | Acebutolol
Tenormin^®^* | Atenolol
Toprol XL^®^* | Metoprolol
Trandate^®^* | Labetalol
Zebeta^®^* | Bisoprolol

* Estos bloqueadores beta están disponibles en forma genérica.

Estatinas
Nombre comercial * | Nombre genérico
Crestor^®^ | Rosuvastatina
Lipitor^®^ | Atorvastatina
Mevacor^®^ | Lovastatina
Pravachol^®^ | Pravastatina
Zocor^®^ | Simvastatina

* Todas estas estatinas están disponibles en forma genéricas, excepto Crestor^®^.

### ¿Qué dicen las investigaciones sobre cuáles medicamentos reducen el riesgo de que la ERC avance hacia la fase terminal?

- En algunas personas con ERC en fase inicial, los IECA y los BRA reducen el riesgo de que la ERC avance hacia la fase terminal. Este beneficio se observó solamente en personas que tienen proteína en la orina y que también tienen presión arterial alta y diabetes.

### ¿Qué dicen las investigaciones sobre otras formas como estos medicamentos pueden ayudar a personas con ERC?

- Los IECA reducen el riesgo de muerte en las personas con ERC que tienen proteína en la orina y que también tienen enfermedades del corazón o de los vasos sanguíneos.
- Los IECA reducen el riesgo de muerte en las personas con ERC que tienen proteína en la orina y que tienen también diabetes con otros factores de riesgo que pueden ocasionar enfermedades del corazón.
- Los bloqueadores beta disminuyen el riesgo de muerte y de ataque al corazón en las personas que tienen ERC e insuficiencia cardiaca.
- Las estatinas disminuyen el riesgo de muerte, de ataque al corazón y de derrame cerebral en las personas que tienen ERC y el colesterol alto.

### ¿Cuáles son los efectos secundarios posibles de estos medicamentos?

#### IECA y BRA

- Según la Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA, por su sigla en inglés) de Estados Unidos, los efectos secundarios más frecuentes que causan los IECA y los BRA son:
  - Tos seca
  - Mareos
  - Cansancio
  - Dolor de cabeza
  - Problemas para dormir
- Los investigadores observaron que:
  - Los IECA y los BRA causan cantidades casi iguales de dolores de cabeza y mareos.
  - La tos seca es más probable en las personas que toman IECA que en las que toman BRA.

La FDA lista las advertencias siguientes sobre los IECA y los BRA:

- Aunque es poco común, los IECA y los BRA pueden causar hinchazón repentina de lengua, labios, garganta, manos o pies. Esto se conoce como “angioedema” y si sucede, debe llamar inmediatamente a su médico. Esto podría ser una emergencia.
- Los IECA y los BRA también pueden causarle un aumento del potasio en la sangre y esto puede ser peligroso. Pero es poco común. Su médico puede ordenarle pruebas de sangre para medir su nivel de potasio mientras está tomando alguno de estos medicamentos.
- Cuando se toman junto con IECA y BRA, los medicamentos antiinflamatorios no esteroideos, como Advil^®^, Motrin^®^, Aleve^®^ y Celebrex^®^, pueden empeorar la función renal. Hable con su médico antes de tomar cualquiera de estos medicamentos si está usted tomando un IECA o un BRA.

#### Bloqueadores beta

- Según la FDA los efectos secundarios más frecuentes que causan los bloqueadores beta son:
  - Cansancio
  - Malestar estomacal
  - Dolor de cabeza
  - Mareos o sensación de desmayo
  - Estreñimiento
  - Diarrea
  - Aumento de peso

#### Estatinas

- De acuerdo con la FDA, los efectos secundarios más frecuentes que causan las estatinas son:
  - Dolor en los músculos y articulaciones
  - Náuseas
  - Estreñimiento
  - Diarrea

Las estatinas pueden causar dolor muscular y en casos poco comunes, daño muscular. Las estatinas también pueden causar daño al hígado, aunque es poco común. Su médico puede ordenarle una prueba de sangre para examinar el hígado cuando empiece a tomar una estatina.

### ¿Qué más puedo hacer?

Debido a que la diabetes o la presión arterial alta pueden causar daño a los riñones, hable con su médico sobre otras cosas que puede hacer para controlar estas condiciones, por ejemplo:

- Llevar una dieta sana, baja en sodio (sal)
- No fumar
- Conservar un peso saludable
- Mantenerse físicamente activo
- Controlar su nivel de azúcar en la sangre si tiene diabetes

Los investigadores estudiaron si determinadas dietas (por ejemplo, una con menos proteína o con menos hierro y carbohidratos) reducían el riesgo de que la ERC avanzara de la fase inicial a la fase terminal o muerte. Al parecer, estas dietas especiales no produjeron cambios, pero no existe suficiente investigación para saberlo con certeza.

### ¿De qué debo hablar con mi médico?

Hay varias cosas que debe considerar al elegir medicamentos que puedan ayudarle con la ERC. Hable con su médico sobre:

- Los beneficios y los posibles efectos secundarios de los IECA, los BRA, los bloqueadores beta y las estatinas
- Qué medicamentos toma usted para otras condiciones y cómo podrían interactuar con un nuevo medicamento
- Por cuánto tiempo necesitará tomar el medicamento
- Con qué frecuencia necesitará hacerse pruebas de sangre y de orina para evaluar la función renal
- Los costos de los medicamentos y cómo se ajustan a su presupuesto

### ¿Cuáles son los costos de estos medicamentos?

Los IECA, los BRA, los bloqueadores beta y las estatinas varían mucho en precio. Muchos de estos medicamentos existen en forma genérica, la cuál cuesta menos que la marca comercial.

El costo para usted de estos medicamentos depende de:

- Su seguro médico
- La dosis (cantidad del medicamento) que necesite tomar
- Si el medicamento está disponible en forma genérica

### Pregunte a su médico

- ¿Qué me está causando ERC?
- ¿Puede otra condición que tengo empeorar mi ERC?
- ¿Me ayudaría un IECA, un BRA, un bloqueador beta o una estatina?
- ¿A qué efectos secundarios graves debo prestar atención?
- ¿Hay otros medicamentos menos costosos que pueda tomar?
- ¿En cuánto tiempo podrá notarse una diferencia en mis riñones?
- ¿Con qué frecuencia debo hacerme las pruebas de los riñones?
- ¿Qué haremos si el medicamento no me ayuda con la ERC?
- ¿Qué más puedo hacer para ayudar con mi ERC?

Otras preguntas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

Anote aquí las respuestas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

## Fuente

La información de este resumen proviene del informe Chronic Kidney Disease Stages 1–3: Screening, Monitoring, and Treatment (Enfermedad renal crónica en fases 1 a 3: detección, vigilancia y tratamiento), de enero de 2012.

El informe fue producido por el University of Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Minnesota), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/ckd.cfm.

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con enfermedad renal leve y diabetes o hipertensión.

Esta guía fue traducida de la publicación en inglés titulada Early Stage Chronic Kidney Disease A Review of the Research for Adults With Kidney Disease and Diabetes or High Blood Pressure.