# Cómo mantener a los niños con un peso saludable

Revisión de las investigaciones sobre formas para evitar el sobrepeso o la obesidad

## ¿Es esta información apropiada para mí?

### Esta información es para usted si

- Usted cuida a un niño que tiene entre 5 y 18 años de edad. Si su hijo tiene menos de 5 años, esta información puede igualmente serle útil.
- Desea saber qué medidas pueden tomarse en la casa, la escuela y la comunidad, para ayudar a los niños a mantener un peso saludable y evitar que tengan sobrepeso o se vuelvan obesos. Si un niño ya tiene sobrepeso o está obeso, aún pueden tomarse medidas para evitar que siga aumentando de peso.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Cómo saber si su hijo tiene un peso saludable
- Qué es el índice de masa corporal (IMC) y qué son los percentiles del IMC
- Qué problemas de salud pueden causar en un niño el sobrepeso o el estar obeso
- Qué puede llevar a un niño a tener sobrepeso o a volverse obeso
- Qué se puede hacer en casa, en la escuela y en la comunidad para ayudar a evitar que los niños tengan sobrepeso o se vuelvan obesos
- Qué han encontrado los investigadores sobre las medidas que se pueden tomar en casa, en la escuela y en la comunidad

Nota: Este resumen no cubre cómo ayudar a los niños a bajar de peso. Habla solamente de cómo evitar que su hijo tenga sobrepeso o se vuelva obeso. Si su hijo tiene sobrepeso, pídale al médico del niño información para ayudarlo a bajar de peso.

Este resumen puede ayudarle a hablar con el médico^*^ del niño, las autoridades escolares y los líderes comunitarios sobre cómo mantener al niño con un peso saludable.

### ¿De dónde proviene la información?

Los investigadores revisaron 124 estudios sobre las maneras de evitar que los niños y los adolescentes se vuelvan obesos. Esos estudios fueron publicados entre noviembre de 1985 y agosto de 2012. Los investigadores fueron financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal.

Los investigadores escribieron un informe sobre sus hallazgos y este resumen se basa en ese informe. El informe fue revisado por médicos, investigadores, otros expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/child-obesity-prevention.cfm (disponible sólo en inglés).

## Aprenda sobre la obesidad en los niños

### ¿Cómo sé si mi hijo tiene un peso saludable?

El médico llevará un control de los cambios de estatura y de peso del niño en el transcurso del tiempo y podrá decirle si el niño tiene un peso saludable. Durante los chequeos médicos regulares, asegúrese de hablar con el médico sobre el peso del niño.

El médico del niño puede preguntarle sobre:

- Los hábitos de alimentación de su hijo
- Si conoce lugares dónde comprar comida sana para el niño
- Cuánta actividad física realiza el niño
- Si hay lugares seguros donde su hijo pueda correr y jugar
- Cuánto tiempo pasa cada día su hijo frente a pantallas (viendo la televisión, jugando con videojuegos o ante la computadora, celular o tabletas, tales como la iPad)
- Cualquier problema de salud que tenga su hijo
- Los antecedentes médicos de su familia

### ¿Qué es el IMC y qué son los percentiles del IMC?

Para saber si su hijo está dentro de un margen de peso adecuado, su médico puede utilizar una medida llamada IMC o “índice de masa corporal”. El IMC es una medida basada en la estatura y el peso de su hijo. El IMC ayuda al médico a calcular cuánta grasa corporal tiene su hijo. El médico puede utilizar el IMC para saber si su hijo tiene un peso apropiado para su estatura. Un IMC saludable es diferente entre las niñas y los niños y cambia según la edad.

Su médico puede comparar el IMC de su hijo con los valores de IMC típicos de los niños de igual sexo y edad. Para eso, los médicos pueden utilizar lo que se llama “percentil del IMC”. Este puede ayudar al médico a establecer si el niño tiene peso bajo, un peso saludable, sobrepeso u obesidad.

De acuerdo con los Centers for Disease Control and Prevention (Centros para el Control y la Prevención de Enfermedades; CDC, por su sigla en inglés), se considera que un niño tiene:

- Un peso saludable si su IMC está entre el percentil 5º y 85º
- Sobrepeso si su IMC está entre el percentil 85º y 95º
- Obesidad si su IMC está en el percentil 95º o superior

Hable con el médico del niño sobre lo que significa el IMC de su hijo.

Para calcular el IMC y el percentil del IMC de su hijo visite http://apps.nccd.cdc.gov/dnpabmi/ (disponible sólo en inglés).

### ¿Qué problemas de salud pueden causarle a un niño el tener sobrepeso o estar obeso?

Los niños que tienen sobrepeso o están obesos tienden más a estar obesos o a tener sobrepeso cuando son adultos. Tienen también una mayor probabilidad de desarrollar problemas de salud graves, como:

- Azúcar alta en la sangre o diabetes
- Presión arterial alta
- Colesterol (un tipo de grasa en la sangre) alto
- Apnea del sueño (condición en la que la persona deja de respirar por lapsos breves durante el sueño)
- Problemas del corazón (como ataque al corazón o insuficiencia cardiaca) o derrame cerebral, en la edad adulta
- Mayor presión en los huesos y articulaciones, que puede causar problemas en la niñez y en la edad adulta, en las articulaciones y huesos
- Enfermedad de hígado graso no alcohólica (enfermedad causada por un exceso de grasa en el hígado)
- Baja autoestima o depresión
- Trastornos de la alimentación, como el atracarse de comida y purgarse

En Estados Unidos, 1 de cada 3 niños tienen sobrepeso o están obesos

### ¿Qué puede ocasionar que un niño tenga sobrepeso o se vuelva obeso?

Muchas cosas pueden hacer que un niño tenga sobrepeso o se vuelva obeso; por ejemplo:

- Hábitos de alimentación no saludables. Los niños pueden comer en exceso, comer muchos alimentos que no son saludables o tomar demasiadas bebidas azucaradas.
- No dormir lo suficiente. Los niños que no duermen el tiempo suficiente cada noche tienden más a tener sobrepeso.
- Antecedentes familiares. Los niños de familias con sobrepeso pueden tener mayor tendencia a desarrollarlo. Eso puede deberse a los genes del niño o a hábitos de alimentación que se aprenden en la familia.
- Falta de actividad física suficiente. Es posible que los niños no realicen suficiente actividad física. Los niños deben estar activos por lo menos 1 hora cada día.
- Demasiado tiempo frente a las pantallas. Los niños pueden pasar demasiado tiempo cada día frente a las pantallas. Algunos niños comen mientras ven la televisión o juegan en la computadora.
- Ambiente. Tal vez los niños pasen el tiempo en un ambiente (como con parientes o amigos, en la guardería o en la escuela) donde no tienen acceso a opciones sanas de alimentación ni oportunidades para hacer actividad física.

## Cómo evitar que su hijo tenga sobrepeso o se vuelva obeso

### ¿Cómo puedo evitar que mi hijo tenga sobrepeso o se vuelva obeso?

Para ayudar a evitar que su hijo tenga sobrepeso o se vuelva obeso, cerciórese de que coma sanamente y se mantenga activo. Hay muchas cosas que se pueden hacer en casa, en la escuela y en la comunidad para ayudar a que los niños mantengan un peso saludable. A continuación, se ofrecen algunos ejemplos de cada una.

#### EN CASA

Hay muchas cosas que la familia puede hacer en casa. Algunos ejemplos son:

Coma sanamente

[image] Prepare comidas sanas en casa con componentes de cada grupo de alimentos.
  - Los grupos de alimentos incluyen frutas, verduras, granos, alimentos con proteínas (como carnes, huevo, pescado, “tofu” o queso de soya y frijoles) y productos lácteos bajos en grasa o sin grasa.
[image] Asegúrese de comer un desayuno sano todos los días.
[image] Coma en la mesa con la familia, en vez de frente a una pantalla (televisión, computadora, teléfono celular o tableta).
[image] Limite o evite tener bebidas y alimentos que no son saludables en casa.
  - Sustituya las meriendas no saludables, como galletas, dulces o patatas fritas en bolsa, por meriendas sanas, como frutas y verduras.
  - Sustituya las bebidas azucaradas no saludables, como los refrescos, bebidas deportivas o jugos, por bebidas sanas, como el agua y la leche baja en grasa o sin grasa.
[image] Siempre que pueda, coma en casa en vez de en restaurantes. En su casa, tendrá mayor posibilidad de limitar la cantidad de grasa, azúcar y sal de sus alimentos.
[image] Asegúrese de comer la cantidad correcta de alimentos.

Si desea más información sobre alimentos sanos, las cantidades correctas y ejemplos de menús, visite http://choosemyplate.gov/en-espanol.html

Manténgase físicamente activo

[image] Dé a su hijo la oportunidad de correr y jugar por lo menos 1 hora al día.
[image] Organice actividades divertidas, como andar en bicicleta, caminar al parque, jugar a la pelota o nadar.
[image] Anime a toda la familia a mantenerse activa a lo largo del día.
  - Por ejemplo, use las escaleras en vez del elevador y vaya a los lugares a pie o en bicicleta en vez de ir en auto o en autobús.
[image] Limite el tiempo que pasa frente a pantallas cada día.
[image] Además de estar físicamente activo, asegúrese de que su hijo duerma lo suficiente cada noche.

Let's Go! (¡Vamos!) es un programa para evitar que los niños se vuelvan obesos. El programa se basa en la alimentación sana y la actividad física.

Let's Go! recomienda los hábitos saludables “5-2-1-0” para cada día:

- 5 frutas y verduras
- 2 horas o menos de tiempo de pantalla para diversión
- 1 hora o más de actividad física
- 0 bebidas azucaradas

Let's Go! también recomienda mantener la televisión y las computadoras fuera del dormitorio del niño y no permitir tiempo de pantalla a los niños menores de 2 años.

Let's Go! es un programa del Estado de Maine que también suministra recursos a las comunidades de otros estados.

Estas imágenes y mensajes están adaptadas de Let's Go! en www.letsgo.org (disponible sólo en inglés)

Let's Go! también tiene recursos para que las escuelas ayuden a los niños a comer sanamente y a estar físicamente activos. Si desea más información y un paquete con recursos para la escuela de su hijo, visite www.letsgo.org/toolkits. Ciertas páginas del paquete de recursos están disponibles en español.

Para saber lo que está haciendo la escuela de su hijo para ayudar a evitar que los niños tengan sobrepeso o se vuelvan obesos, hable con el director, la enfermera escolar o el consejero de la escuela de su hijo. También puede preguntar cómo participar en la Asociación de Padres y Profesores (PTA, por su sigla en inglés) o en la Organización de Padres y Profesores (PTO, por su sigla en inglés).

### En la escuela

Además de comer sanamente y estar físicamente activos en casa, los programas escolares pueden ayudar a los niños a mantener un peso saludable. Los programas escolares pueden incluir actividades como las siguientes:

- Lecciones sobre la importancia de la alimentación sana y la actividad física.
- Sesiones de información para que los padres aprendan maneras de ayudar a su niño a mantener un peso saludable.
- Opciones sanas para el desayuno y el almuerzo en la cafetería, con tamaños adecuados de las porciones.
- Meriendas y bebidas sanas en las máquinas expendedoras y en las fiestas y eventos.
- Dispensadores de agua con filtros, para promover el uso de agua potable en vez de refrescos o bebidas deportivas.
- Grupos guiados por adultos para ir a la escuela a pie o en bicicleta.
- Un período más largo de educación física, en el que los niños estén físicamente activos.
- Equipo de gimnasia, como pelotas y cuerdas para saltar, para usar en el recreo.

### En la comunidad

Además de en la casa y la escuela, se pueden hacer cambios también en la comunidad para ayudar a que los niños mantengan un peso saludable. Las comunidades y los centros comunitarios pueden:

- Mejorar los parques, las aceras y vías para montar bicicleta en la comunidad.
- Tomar medidas para que los parques, las aceras y las vías para montar bicicleta sean seguros.
- Anunciar eventos comunitarios tales como ferias de la salud, caminatas de 5 kilómetros (5K), eventos deportivos en los parques locales, programas de huertos comunitarios y mercados de agricultores locales. Esto se puede hacer mediante carteles, los periódicos locales y las estaciones de radio y televisión locales.
- Ofrecer programas donde las familias puedan recibir consejos sobre alimentación sana y actividad física.

Para conocer otros recursos que pueden ayudar a su hijo a mantener un peso saludable, visite:

- Iniciativa Let's Move! (¡A moverse!) de la Primera Dama Michelle Obama: www.letsmove.gov/en-espanol
- We can! (¡Podemos!) de los National Institutes of Health (Institutos Nacionales de la Salud): www.nhlbi.nih.gov/ health/public/heart/obesity/wecan/espanol
- Healthy Children de la American Academy of Pediatrics (Academia Estadounidense de Pediatría): www.healthychildren.org/spanish/paginas/default.aspx

Si desea más información para mejorar los parques, aceras y vías para montar bicicleta en su zona, póngase en contacto con su departamento local de parques y recreación.

Si desea más información sobre eventos o programas en su comunidad, póngase en contacto con sus centros comunitarios y recreativos locales (como la YMCA, el Boys and Girls Club o los centros comunitarios religiosos locales).

### ¿Qué han encontrado los investigadores sobre medidas que pueden tomarse en el hogar, la escuela y la comunidad para evitar que los niños tengan sobrepeso o se vuelvan obesos?

Una alimentación sana y la actividad física son muy importantes para evitar que los niños tengan sobrepeso o se vuelvan obesos.

Los investigadores observaron que:

- Los programas escolares para ayudar a los niños a comer sanamente y a estar físicamente activos pueden ayudar a evitar que tengan sobrepeso o se vuelvan obesos.
- En conjunto con los programas escolares, pueden serle útiles también otras medidas que se tomen en casa y en la comunidad.
- Se necesitan más investigaciones para saber qué programas o medidas son más eficaces.

## Cómo hablar con el médico de su hijo, las autoridades escolares y los centros comunitarios

### Ejemplos de preguntas para el médico de su hijo

- ¿Está mi hijo en un peso saludable?
- ¿Cuáles son las cosas más importantes que debo hacer en casa para ayudar a mi hijo a mantener un peso saludable?
- ¿Cómo puedo hacer que mi hijo coma alimentos sanos?
- ¿Qué cantidad de cada tipo de alimento debe comer mi hijo?
- ¿Qué tanta actividad física necesita mi hijo cada día?
- ¿Cuáles son los mejores tipos de actividad física para mi hijo?
- ¿Cuánto tiempo debo permitir que pase mi hijo frente a las pantallas cada día?
- ¿Cuánto tiempo debe dormir mi hijo cada noche?
- ¿Tiene usted recursos que puedan ayudarme a mantener a mi hijo en un peso saludable?
- ¿Conoce usted de recursos comunitarios que puedan ayudar?
- Si no tengo tiendas de comestibles cerca o los alimentos sanos resultan costosos para mí, ¿conoce usted de recursos que puedan ayudarme?
- Si no hay un lugar seguro para que mi hijo salga a jugar, ¿cómo puedo ayudarlo a mantenerse activo?

### Ejemplos de preguntas para el director, la enfermera o el consejero escolar de su hijo

- ¿La escuela ofrece programas para ayudar a evitar que los niños tengan sobrepeso o se vuelvan obesos? Si no, ¿cómo podríamos iniciar alguno?
- En la cafetería y las máquinas expendedoras, ¿se ofrecen alimentos sanos, como frutas y verduras, en vez de bebidas azucaradas y alimentos salados o grasosos?
- ¿Cuánto tiempo se da a mi hijo para actividades físicas en la clase de educación física, en el recreo o durante el día?
- ¿Emplea la escuela alguna vez como castigo la educación física u otras actividades físicas?
- ¿Tienen ustedes programas de caminatas en grupo para ir a la escuela o grupos para ir en bicicleta a la escuela guiados por adultos u otros programas de actividad física para los niños?
- ¿Hay sesiones de información a las que pueda asistir para aprender más sobre cómo ayudar a mi hijo a mantener un peso saludable?
- ¿Qué puedo hacer en casa para ayudar a reforzar lo que se le enseña en la escuela sobre la alimentación sana y la actividad física?
- ¿Sabe usted de recursos comunitarios que puedan ayudar?

### Ejemplos de preguntas para sus centros comunitarios o recreativos locales

- ¿Tienen ustedes recursos o programas sobre alimentación sana o actividades físicas para los niños?
- ¿Tienen un calendario de eventos comunitarios que incluya actividades como ferias de la salud, caminatas de 5 kilómetros (5K) o eventos deportivos en los parques locales?
- ¿Tienen una lista de huertos comunitarios o mercados de agricultores locales?
- ¿Saben de programas que puedan orientarme para ayudar a mi familia a comer sanamente y a estar físicamente activa?

## Fuente

La información de este resumen proviene del informe Childhood Obesity Prevention Programs: Comparative Effectiveness Review and Meta-Analysis, (Programas para la prevención de la obesidad infantil: Revisión de eficacia comparada y metaanálisis), de junio de 2013. El informe fue producido por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Johns Hopkins) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Si desea una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/children-obesity-prevention.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas) en el Baylor College of Medicine (Facultad de Medicina de Baylor), en Houston, Texas. Este resumen fue revisado por padres de niños entre 2 y 18 años de edad.

Esta guía fue traducida de la publicación en inglés titulada Keeping Children at a Healthy Weight: A Review of the Research on Ways To Avoid Becoming Overweight or Obese.

* En este resumen, el término “médico” se refiere al profesional de la atención médica que atiende al niño, como su pediatra, médico familiar, enfermera o asistente médico.