# Tratamiento y prevención de las infecciones intestinales causadas por el microbio Clostridium difficile

Revisión de la investigación para adultos y personas que ayudan a su cuidado

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Ha tenido diarrea acuosa con cólicos leves, tres o más veces al día durante varios días, particularmente después de que ha estado tomando un antibiótico o ha estado hospitalizado.
- Su médico o profesional de atención médica le ha dicho que está infectado por un microbio llamado Clostridium difficile, conocido también como “C. difficile” o “C-diff”.

Este resumen le ofrece información obtenida de la revisión más reciente de investigaciones sobre las infecciones por C-diff, para ayudarle a entender sus opciones de tratamiento y las formas de evitar futuras infecciones.

### No es apropiada si

- Su profesional de atención médica le ha dicho que la diarrea u otros síntomas que tiene usted, o la persona a la que cuida, se deben a una infección causada por un tipo diferente de bacteria o virus.

### ¿De dónde proviene la información?

La información proviene de la revisión de 102 estudios acerca de la prevención y tratamiento de las infecciones por C-diff. Investigadores independientes realizaron esta revisión para la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés), organismo del gobierno federal. Puede leer el informe completo en www.effectivehealthcare.ahrq.gov/cdiff.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es Clostridium difficile?

Clostridium difficile es un microbio que puede encontrarse en muchos sitios, incluso el suelo, el agua y el aire. A veces se le llama también “C. difficile” o “C-diff”.

Algunos tipos de microbios C-diff producen sustancias químicas o “toxinas”. Los microbios C-diff productores de toxinas pueden enfermar a ciertas personas.

### ¿Cómo se produce la infección por C-diff?

Los intestinos contienen muchos microbios “buenos” que nos ayudan a digerir los alimentos. El microbio C-diff entra en el cuerpo cuando la persona come o ingiere algo que lo contiene. El microbio avanza hasta los intestinos. Una persona sana con un sistema inmunológico normal y microbios “buenos” normales, puede no enfermarse. Pero si su sistema inmunológico está débil o los microbios buenos fueron destruidos por un “antibiótico” que esté tomando por otro tipo de infección, el C-diff puede proliferarse dentro de los intestinos y causar diarrea. A esto se le llama infección por C-diff.

## ¿Qué factores aumentan el riesgo de adquirir una infección por C-diff?

Su riesgo de adquirir una infección por C-diff puede aumentar si:

- Ha estado tomando un antibiótico durante los últimos 30 días. Los antibióticos pueden matar a los microbios “buenos” de los intestinos.
- Tiene un sistema inmunológico débil por causa de una enfermedad crónica (persistente).
- Es una mujer de 65 años o más.
- Usted toma medicamentos para la acidez estomacal o para reducir el ácido del estómago; por ejemplo, Prevacid^®^, Tagamet^®^, Prilosec^®^ o Nexium^®^.
- Usted estuvo hospitalizado, especialmente en una unidad de terapia intensiva, o vive en un hogar de ancianos.

Las infecciones por C-diff ocurren con mayor frecuencia en hospitales, hogares de ancianos u otros lugares donde hay más personas enfermas o que están tomando antibióticos.

### ¿Pueden repetirse las infecciones por C-diff?

Una de cada cinco personas que reciben tratamiento a causa de una infección por C-diff, verán que ésta regresa de 8 a 10 semanas después de terminado el tratamiento completo con medicamentos. Los investigadores no saben a qué se debe esto.

### ¿Es peligrosa una infección por C-diff?

Algunos pacientes con infecciones por C-diff pueden enfermar gravemente. En casos raros, una infección por C-diff puede obligar a la extirpación del intestino. La persona puede incluso morir. Es importante saber cómo evitar y tratar una infección por C-diff, sobre todo si usted está en riesgo.

### ¿Cuáles son los síntomas de una infección por C-diff?

Los síntomas de una infección leve a moderada por C-diff son:

- Diarrea acuosa 3 o más veces al día, durante 2 días o más.
- Cólicos y sensibilidad leves en el abdomen (vientre).

### Los principales síntomas de una infección grave por C-diff son

- Diarrea acuosa muchas veces, durante el día y la noche.
- Cólicos y dolor abdominal muy intensos.
- Fiebre.
- Sangre o pus en el excremento.
- Náuseas.
- Cantidad insuficiente de agua en el cuerpo (llamada “deshidratación”).
- Pérdida del apetito.
- Pérdida de peso.

No se avergüence de hablar de estos síntomas con su médico. ¡La infección por C-diff es una enfermedad peligrosa que necesita tratamiento!

## Conozca sus opciones

### ¿Qué tratamientos sirven para tratar las infecciones por C-diff?

#### Antibióticos para tratar infecciones por C-diff la primera vez

El C-diff es un microbio, lo que significa que puede destruirse usualmente con medicamentos llamados antibióticos. Su médico puede recetarle uno de los siguientes antibióticos:

- Fidaxomicina. El nombre comercial común de este medicamento es Dificid^®^.
- Metronidazol. El nombre comercial común de este medicamento es Flagyl^®^.
- Vancomicina oral. El nombre comercial común de este medicamento es Vancocin^®^.

Las investigaciones mostraron que los tres antibióticos pueden curar con igual eficacia su primera infección por C-diff. Sin embargo, la infección por cierto tipo de C-diff (llamado cepa no norteamericana tipo 1 de campo pulsado, o no-NAP1, por su sigla en inglés) se repitió en un menor número de personas después de que tomaron fidaxomicina.

### ¿Qué puedo hacer si se me repite la infección por C-diff?

Es frecuente que la infección por C-diff se repita, quizás hasta varias veces, después de la primera infección. Si esto sucede, es posible que su médico le recete otro ciclo del mismo antibiótico o uno diferente, o que pruebe con diferentes dosis o combinaciones de estos medicamentos.

Tome siempre los antibióticos como se lo indique su médico. Eso significa ¡tomar todo el medicamento que le recetaron para tratar la infección!

### ¿De qué otros tratamientos se habla y funcionan?

Posiblemente lea o escuche de tratamientos “no estándar” (sin antibióticos) que un médico pueda usar cuando los tratamientos antibióticos estándar no funcionan para evitar que se repitan las infecciones por C-diff. Estas opciones no se usan tanto y a veces se combinan con antibióticos. Puede que algunas de estas opciones no las cubran las pólizas normales de seguro médico o no estén disponibles en su área.

### Tratamientos que muestran cierta promesa, aunque no totalmente demostrada

- Suero inmune Clostridium difficile (CDIW, por su sigla en inglés).
  El CDIW se elabora con leche de vacas que son inmunes a C-diff (es decir, que no pueden infectarse con el microbio). Este líquido, de aspecto similar a la leche, se toma como cualquier otra bebida.
- Prebióticos.
  Los prebióticos son alimento para los microbios buenos del organismo. Pueden ayudar a proteger los intestinos de los microbios malos, como C-diff. Existen en forma natural en ciertos alimentos o pueden tomarse como suplementos.
- Anticuerpos neutralizadores de toxinas.
  Los anticuerpos neutralizadores de toxinas son un tipo de medicamento que bloquea las toxinas producidas por los microbios C-diff. Estos medicamentos se administran por venoclisis (un tubo intravenoso que se afianza en el brazo con una aguja).
- Reposición de los microbios sanos (reconstitución de la flora intestinal).
  Los médicos obtienen de un familiar cercano, no infectado, materia fecal normal que contiene microbios sanos y la colocan en el intestino del paciente.

### Tratamientos que no han mostrado promesa

- Probióticos.
  Los probióticos son microbios buenos que se pueden ingerir para ayudar a combatir la enfermedad. Algunas investigaciones descubrieron que la adición de probióticos al tratamiento con antibióticos NO ayudó a curar las infecciones por C-diff. Los investigadores observaron que el uso de ciertos probióticos en pacientes críticamente enfermos con una infección por C-diff puede aumentar el riesgo de adquirir una infección por hongos que pueda causar la muerte.

## ¿Cómo se pueden prevenir las infecciones por C-diff?

### Mediante el uso prudente de los antibióticos

- Tome antibióticos solamente cuando tenga una infección causada por bacterias. Los antibióticos no ayudan a curar todas las infecciones. Por ejemplo, los antibióticos no ayudan a destruir los virus del resfriado común, ni otros virus. Su médico puede ayudarle a decidir si necesita un antibiótico para tratar una enfermedad.
- Cuando necesite un antibiótico, lo mejor es que use uno diseñado para destruir el tipo específico de microbio que está causando la infección (lo que se llama un antibiótico de “espectro reducido”), si está disponible. Los antibióticos que matan muchos tipos de microbios (llamados “de amplio espectro”) pueden también matar a microbios buenos que le protegen contra C-diff. Asegúrese de preguntar a su médico si el antibiótico que le receta conlleva un riesgo alto de infección por C-diff.
- Si tiene una infección, es posible que su médico le recete un antibiótico de amplio espectro. Después, puede que lo cambie a un antibiótico de espectro reducido. El médico se basará en los resultados de los exámenes que indican qué microbios le causan la infección.
- Asegúrese siempre de tomar solamente el antibiótico que le recetaron y de tomarlo todo.

### Si tiene usted C-diff en el hospital u hogar de ancianos

Los microbios C-diff pueden permanecer en la ropa de cama, las barandillas de la cama, los accesorios del baño y en los instrumentos médicos.

- Los médicos y las enfermeras deben usar guantes y batas desechables cuando lo atiendan.
- Todos los médicos, enfermeras y demás personal deben seguir siempre las normas apropiadas de higiene para manos y establecidas por el hospital u hogar de ancianos donde usted está.
- El hospital u hogar de ancianos debe utilizar productos de limpieza que puedan destruir los microbios C-diff.

### Si usted visita a alguien con C-diff en el hospital u hogar de ancianos

Por lo general, las infecciones por C-diff no ocurren en personas que no están tomando antibióticos. Si usted no tiene riesgo de adquirir C-diff, es improbable que contraiga la infección. Sin embargo, podría transmitir el microbio sin darse cuenta.

- Solamente el paciente con C-diff debe usar el baño de su habitación.
- Es posible que necesite usar guantes y bata desechables.
- Lávese las manos con agua y jabón al entrar o salir del cuarto.

### Si está en casa

- Lávese las manos frecuentemente con agua y jabón, sobre todo después de usar el baño y antes de comer o preparar alimentos.
- Todos los que viven en la casa deben lavarse las manos a menudo.

## Hable con su médico acerca del C-diff

A continuación se mencionan algunas preguntas que tal vez quiera hacer a su médico o profesional de atención médica acerca de las infecciones por C-diff.

### Cuando le prescriban un antibiótico para una infección que no sea causada por C-diff

- ¿Este antibiótico es de espectro amplio o reducido?
- Si estoy en riesgo de adquirir una infección por C-diff, ¿hay algún antibiótico de espectro reducido que pueda tomar?

### Si está experimentando por primera vez una infección por C-diff

- ¿Qué antibiótico cree que funcione mejor para mi infección por C-diff?
- ¿Cuanto tiempo tardarán en desaparecer mis síntomas?
- ¿Si los síntomas desaparecen y luego regresan, quiere decir que tengo otra vez la infección por C-diff?
- ¿Hay algún plan de tratamiento que pueda ayudarme a lograr que la infección por C-diff no se repita?

Otras preguntas que puede hacerle a su médico u otro profesional de atención médica:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) de Houston, Texas.

Se basa en un informe de investigación producido por el University of Minnesota Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Minnesota), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por su sigla en inglés).

Para obtener una copia del informe o si desea mayor información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite la página www.effectivehealthcare.ahrq.gov/cdiff.cfm (disponible sólo en inglés).

La información de esta guía proviene del informe Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection (‘Eficacia del diagnóstico, prevención y tratamiento oportuno de la infección por Clostridium difficile’), diciembre de 2011. Los resultados de este informe se publicaron también en el artículo “Comparative Effectiveness of Clostridium difficile Treatments: A Systematic Review” (‘Comparación de la efectividad de los tratamientos contra Clostridium difficile: revisión sistemática’), el 20 de diciembre de 2011 en la revista Annals of Internal Medicine.