# Coordinación del cuidado de adultos con afecciones médicas prolongadas

Revisión de los estudios de investigación

## ¿Es esta información apropiada para mí?

### Si cumple con todas las características siguientes, esta información es para usted

- Usted o la persona a quien cuida tiene una o más afecciones médicas prolongadas, como insuficiencia cardiaca congestiva, cáncer, diabetes, demencia o tuberculosis (llamada también TB).
- Está considerando utilizar la administración de casos (cuando una enfermera o trabajador social le ayuda a resolver sus necesidades de atención o las de la persona a quien cuida). Tal vez un médico^*^ o un proveedor de seguros le sugirió que utilizara la administración de casos.
- Usted tiene 18 años o más. La información de este resumen proviene de investigaciones en adultos.

Nota: Este resumen no cubre la administración de casos para pacientes con enfermedades psiquiátricas tales como depresión, esquizofrenia o trastorno bipolar. Si desea información sobre la administración de casos para personas con enfermedades psiquiátricas, pregunte a su médico.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Qué es la administración de casos y a quién le puede servir
- Qué han encontrado los investigadores sobre la administración de casos para personas con afecciones médicas prolongadas

Este resumen puede ayudarle a decidir si la administración de casos puede ser apropiada para usted o para la persona a quien cuida.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 109 estudios sobre la administración de casos para personas con afecciones médicas prolongadas, publicados hasta agosto de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/case-management.cfm (disponible sólo en inglés).

## Conozca sobre la administración de casos

### ¿Qué es la administración de casos?

La administración de casos es un servicio en el que una enfermera o trabajador social ayudan a administrar o coordinar los cuidados de una persona con una afección prolongada. La atención de las personas con afecciones prolongadas puede ser compleja y necesitar de la participación de diferentes médicos y tratamientos.

Un administrador de casos puede servir de enlace entre el paciente o su proveedor de atención y sus médicos, el sistema de atención médica y los recursos comunitarios. Los administradores de casos pueden reunirse con los pacientes y sus proveedores de atención en su casa, en el consultorio, la clínica o por teléfono.

El administrador de casos puede ayudar tanto con funciones médicas como con la coordinación de los cuidados.

Las funciones médicas pueden consistir en ayudar a los pacientes a
- Entender mejor su enfermedad y su plan de atención
- Estar atento a los cambios en su enfermedad
- Colaborar con su médico para asegurarse de que reciben el cuidado apropiado
- Colaborar con su médico para ajustar los medicamentos
- Seguir las instrucciones de atención del médico
  - Por ejemplo, ayudar a los pacientes a tomar sus medicamentos, medirles el azúcar en la sangre, tomarles la presión arterial o para seguir una dieta determinada
- Aprender a controlar su enfermedad

Coordinar la atención puede consistir en ayudar a los pacientes a
- Entender como usar y navegar por el sistema de atención médica y su plan de seguro médico
- Mantenerse en contacto con todos sus médicos u otros profesionales de la atención médica
- Hacer citas para consultas médicas, pruebas médicas o sesiones de tratamiento
- Establecer contacto con recursos útiles que se ofrecen en la comunidad.
  - Por ejemplo, grupos de apoyo, grupos que proporcionan alimentos o transporte y servicios que permiten que los proveedores de atención tomen descansos

### ¿A quiénes puede ayudar la administración de casos?

La administración de casos puede ayudar a las personas con necesidades de atención complejas, como aquellas con:

- Muchas enfermedades prolongadas
- Insuficiencia cardiaca congestiva
- Cáncer
- Tuberculosis (TB)
- Diabetes
- Demencia (deterioro de la memoria, confusión y agitación causadas por afecciones como la enfermedad de Alzheimer)

### ¿Cómo se consigue un administrador de casos?

Algunos médicos asignan un administrador de casos a los pacientes que consideran se beneficiarán de este apoyo adicional. A menudo, los proveedores de seguros médicos ofrecen la administración de casos a los pacientes con afecciones médicas prolongadas. Es posible que su proveedor de seguro médico le envíe una carta acerca de la administración de casos.

Los diferentes proveedores de seguro médico pueden darle nombres distintos a la administración de casos; por ejemplo, “manejo de enfermedades”, “coordinación de cuidados” o “apoyo para la autoasistencia”. Algunos tipos de “atención médica en el hogar” pueden incluir la administración de casos. Usted o su médico pueden consultar a su proveedor de seguro médico para saber si usted o la persona a quien cuida tiene cobertura para administración de casos.

### ¿Qué han encontrado los investigadores sobre la administración de casos en las personas con afecciones médicas prolongadas?

Los investigadores encontraron que la administración de casos parece ser más eficaz cuando los administradores de casos:

- Tienen una colaboración estrecha con los médicos u otros profesionales que atienden a los pacientes
- Colaboran estrechamente con los pacientes o sus proveedores de atención durante un período de tiempo largo
- Hablan en persona con los pacientes o sus proveedores de atención y no solamente por teléfono

Los investigadores encontraron también estos resultados acerca de las personas que utilizaron la administración de casos para diferentes enfermedades:
Las personas de edad avanzada con más de una enfermedad prolongada:; - Consideraban que sus cuidados estaban mejor coordinados; - No tuvieron una mejor capacidad para hacer sus tareas cotidianas (como vestirse, bañarse u otras labores de autoasistencia); - No acudieron al hospital con menos frecuencia
Las personas con insuficiencia cardiaca congestiva:; - Se sintieron más satisfechas con su cuidado; - Pudieron seguir mejor las instrucciones de su médico
Las personas con cáncer:; - Se sintieron más satisfechas con su cuidado; - Pudieron obtener con más facilidad la atención recomendada para su tipo de cáncer (por ejemplo, tratamientos de radioterapia o quimioterapia)
Las personas con diabetes:; - Al parecer, pudieron controlar mejor su glucosa (azúcar) en la sangre, pero se necesitan más investigaciones para saberlo con certeza; - No tuvieron controlar mejor sus lípidos (tipo de grasa presente en la sangre) ni su peso
Los proveedores de atención para las personas con demencia:; - Tenían menos estrés y depresión; - No pudieron retrasar el colocar a la persona a quien cuidaban en un hogar de ancianos cuando la administración del caso había durado 2 años o menos
Las personas con demencia:; - No tuvieron menos problemas de conducta
Las personas con tuberculosis:; - Tuvieron una mayor posibilidad de que su tratamiento fuera eficaz

## Tome una decisión

### ¿En qué cosas debo pensar?

Se deben considerar muchos aspectos al decidir si la administración de casos sería apropiada para usted o la persona a quien cuida.

Debe usted pensar en
- Los beneficios probables de la administración de casos
- La capacidad que tenga para reunirse con un administrador de casos
- Qué tan cómodo se sienta de que alguien le ayude a resolver sus necesidades de atención o las de la persona a quien cuida
- Qué tan cómodo se siente de que alguien vaya a hablar con usted en su casa

### ¿Cuáles son los costos de la administración de casos?

Los proveedores de seguro médico pueden cubrir el costo de la administración de casos para los pacientes con enfermedades prolongadas. Comuníquese con su proveedor de seguro médico si desea más información.

### Pregunte a su médico

Para responder algunas de estas preguntas, es probable que usted y su médico tengan que hablar con su proveedor de seguro médico:

- ¿Cree usted que la administración de casos pueda ayudarme?
- ¿Se puede conseguir un administrador de casos a través de su consultorio o de mi proveedor de seguro médico?
- ¿Se pondrá usted en contacto con mi proveedor de seguro médico o debo contactarlo yo?
- ¿Cuánto tiempo trabajará conmigo el administrador de casos?
- ¿Con qué frecuencia se reunirá conmigo el administrador de casos?
- ¿Dónde hablaré con el administrador de casos: en mi casa, en el consultorio o la clínica, o por teléfono?
- ¿Con qué tareas específicas podría ayudarme un administrador de casos?
- ¿El administrador de casos trabajará directamente con usted y mis otros médicos y profesionales de atención médica?
- ¿Me acompañará el administrador de casos a alguna de mis consultas médicas?
- ¿Existe alguna razón para no tener un administrador de casos?

### Pregunte a su proveedor de seguro médico

- ¿Puedo conseguir un administrador de casos para mí o la persona a quien cuido?
- ¿Mi seguro médico cubre por completo la administración de casos? ¿Necesitaré pagar algo?
- ¿Cómo me inscribo para obtener un administrador de casos?

## Fuente

La información de este resumen proviene del informe Outpatient Case Management for Adults With Medical Illness and Complex Care Needs (Administración de casos ambulatoria para adultos con enfermedad médica y necesidades complejas de atención), de enero de 2013. Fue producido por el Oregon Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Oregon), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/case-management.cfm (disponible sólo en inglés).

Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con afecciones médicas prolongadas o por sus proveedores de atención.

Esta guía fue traducida de la publicación en inglés titulada Managing Care for Adults With Long-term Medical Illnesses: A Review of the Research.

* En este resumen, el término “médico” se refiere al profesional de la atención médica que lo atiende, como puede ser su médico familiar, especialista, enfermera o asistente médico.