# Reduzca el riesgo de cáncer del seno con medicamentos

Guía para la mujer

## Hechos resumidos

- La mayoría de las mujeres jamás tendrá cáncer del seno.
- El riesgo de que una mujer tenga cáncer del seno aumenta con la edad.
- Existen dos medicamentos diferentes capaces de reducir el riesgo de padecer algunos tipos de cáncer del seno.
- Ambos medicamentos tienen efectos secundarios y a veces causan problemas graves.

## ¿Qué cubre esta guía?

Esta guía puede ayudarle a hablar con su médico o enfermera acerca de los medicamentos para reducir su riesgo de contraer cáncer del seno. Esta guía trata acerca de dos medicamentos diferentes y contiene información sobre los beneficios, efectos secundarios y costos.

Esta guía se basa en una revisión, financiada por el gobierno, de los informes de investigación sobre el uso de medicamentos para reducir el riesgo de cáncer del seno.

## ¿Qué no cubre esta guía?

Esta guía no cubre otras formas de reducir su riesgo de tener cáncer del seno. No trata sobre el hacerse cirugía para reducir el riesgo de cáncer del seno. Tampoco incluye cómo reducir el riesgo de contraer cáncer del seno en hombres, ya que estos medicamentos no han sido estudiados en hombres.

Esta guía no incluye información acerca de los exámenes de detección del cáncer del seno. Tampoco incluye los tratamientos para mujeres que ya tengan cáncer del seno.

## El riesgo de tener cáncer del seno

La mayoría de las mujeres jamás tendrá cáncer del seno. El riesgo de que una mujer tenga cáncer del seno depende de su edad y de otros factores de riesgo. No existen otros factores de riesgo para la mayoría de mujeres con cáncer del seno, excepto el avanzar en edad. Además, muchas mujeres con factores de riesgo, no relacionados con la edad, nunca llegan a tener cáncer del seno.

El gráfico a continuación muestra cuántas mujeres (de cada 100) tendrán cáncer del seno a lo largo de los próximos 10 años. El riesgo de tener cáncer del seno aumenta con la edad. Al encontrar su edad actual, podrá saber cuál es el riesgo que tiene alguien en su rango de edad.

Cantidad de mujeres que contraerán cáncer del seno durante los próximos 10 años

Edad | Riesgo estimado
30 a 39 | Menos de 1 de cada 100
40 a 49 | Aproximadamente 1 de cada 100
50 a 59 | Aproximadamente 2 de cada 100
60 a 69 | Aproximadamente 3 de cada 100
70 a 79 | Aproximadamente 4 de cada 100

Riesgo estimado para las mujeres en los Estados Unidos. Esta información deriva del Surveillance, Epidemiology and End Results (Vigilancia, epidemiología y resultados finales, SEER por sus siglas en inglés) de la revisión de estadísticas del cáncer, 1975–2005, del National Cancer Institute (Instituto Nacional del Cáncer).

### Factores de riesgo del cáncer del seno

#### Edad

El riesgo de contraer cáncer de seno aumenta con la edad.

#### Antecedentes familiares

El tener una madre, hermana o hija que haya tenido cáncer del seno aumenta su riesgo.

#### Antecedentes de biopsias del seno

El tener un resultado anormal en una biopsia del seno anterior aumenta el riesgo de contraer cáncer del seno.

#### Antecedentes menstruales

El tener la primera menstruación a una edad temprana (antes de los 12 años), aumenta su riesgo. Entrar en la menopausia a una edad tardía (después de los 55), aumenta su riesgo.

#### Antecedentes reproductivos

Tener el primer hijo a una edad más avanzada aumenta su riesgo de cáncer del seno. No tener hijos también aumenta su riesgo.

#### Terapia de hormonas para la menopausia

Tomar hormonas para la menopausia (estrógeno solo o estrógeno con progestina) aumenta su riesgo.

#### Obesidad

El ser obeso (tener mucho sobrepeso) aumenta el riesgo de contraer cáncer del seno.

#### Consumo de bebidas alcohólicas

Tomar más de una o dos bebidas al día aumenta su riesgo.

#### Otros factores de riesgo

Es poco frecuente, pero algunas mujeres nacen con un gen que aumenta su riesgo de tener cáncer del seno. El recibir tratamientos de radiación a una temprana edad también aumenta su riesgo.

## Aprenda sobre el cáncer del seno

El cáncer del seno es un tumor maligno que comienza en las células del seno. Maligno significa que las células son cancerosas y pueden esparcirse a otros tejidos en el seno. A veces, las células cancerosas se esparcen fuera del seno, a otras partes del cuerpo. Esto quiere decir que hacen metástasis.

Los conductos del seno llevan la leche al pezón. La mayoría de los cánceres comienza en las células que conforman los conductos galactóforos. Algunos cánceres del seno empiezan en los lobulillos (glándulas donde se produce la leche materna).

Una biopsia del seno es la única forma de saber si las células del seno son anormales o cancerosas. En una biopsia del seno, el médico extrae una pequeña porción de tejido del seno. El tejido se observa con un microscopio para verificar que no haya cambios. Si las células son anormales o cancerosas, una biopsia puede mostrarle si están en un solo lugar o si ya han comenzado a esparcirse.

### Cáncer del seno no invasivo

Un cáncer del seno no invasivo es un crecimiento de células anormales situado en el seno. En este caso, las células no se han esparcido a otros tejidos en el seno o al resto del cuerpo.

- Carcinoma lobulillar in situ (LCIS por sus siglas en inglés) - En el caso de LCIS, las células anormales crecen dentro de los lobulillos. “In situ” significa “en el lugar.” Las células anormales se han quedado en un solo lugar. El LCIS rara vez se transforma en un cáncer invasivo. Sin embargo, las mujeres con LCIS tienen un riesgo mayor de tener cáncer del seno invasivo.
- Carcinoma ductal in situ (DCIS por sus siglas en inglés) - En el caso de DCIS, las células anormales crecen dentro de los conductos galactóforos. Se le llama “in situ” porque las células anormales se encuentran en un solo lugar. El DCIS es el tipo más común de cáncer del seno no invasivo. Existe la posibilidad de que el DCIS se transforme en cáncer invasivo con el tiempo.

### Cáncer del seno invasivo

En el caso del cáncer del seno invasivo, las células anormales se han esparcido más allá del lugar en el que comenzaron. El cáncer del seno invasivo puede originarse en los conductos galactóforos o en los lobulillos. “Invasivo” quiere decir que las células cancerosas se han esparcido a otros tejidos del seno.

## Sobre los medicamentos

Existen dos medicamentos distintos capaces de reducir el riesgo de contraer cáncer del seno en mujeres que nunca lo han tenido.

- Raloxifeno. Su uso está aprobado únicamente después de la menopausia.
- Tamoxifeno. Su uso está aprobado antes y después de la menopausia.

Se debe tomar el tamoxifeno o raloxifeno una vez al día durante no más de 5 años para reducir el riesgo de cáncer del seno.

### Cómo funcionan

El estrógeno es una hormona natural del cuerpo. Algunos cánceres del seno utilizan el estrógeno para crecer. Hay un lugar en algunas células del cáncer del seno, llamado receptor, donde puede adherirse el estrógeno. A este tipo de cáncer del seno se le llama cáncer positivo para receptores de estrógenos.

El tamoxifeno y el raloxifeno bloquean el estrógeno. Se adhieren al receptor, para evitar que el estrógeno lo haga. Este tipo de célula de cáncer del seno no puede multiplicarse ni crecer sin el estrógeno.

Algunos cánceres del seno no tienen receptores de estrógeno. A este tipo de cáncer del seno se le llama cáncer negativo para receptores de estrógenos. No es tan común, pero es más difícil de tratar.

- El raloxifeno y el tamoxifeno reducen el riesgo de tener cánceres del seno con receptores de estrógeno.
- No reducen el riesgo de cánceres del seno sin receptores de estrógeno.

## Posibles beneficios

Tanto el tamoxifeno como el raloxifeno reducen el riesgo de tener cáncer del seno invasivo en un 50 por ciento en las mujeres que nunca lo han tenido.

Este gráfico muestra el riesgo total para las mujeres en los Estados Unidos desde los 50 hasta los 59 años. Su riesgo de tener cáncer del seno invasivo a lo largo de los próximos 10 años es de aproximadamente 2 de 100. Esto quiere decir que de cada 100 mujeres, aproximadamente 2 tendrán cáncer del seno. Si todas esas 100 mujeres tomaran medicamentos para reducir su riesgo de contraer cáncer del seno, sólo la mitad (1 mujer) tendría cáncer del seno.

El raloxifeno no reduce el riesgo de cánceres del seno no invasivos (LCIS y DCIS). Las investigaciones todavía no pueden determinar el efecto del tamoxifeno en los cánceres no invasivos.

## Problemas posibles

Tanto el tamoxifeno como el raloxifeno tienen efectos secundarios comunes. Ambos pueden causar sofocos. El tamoxifeno puede causar síntomas vaginales, como picazón, sequedad o secreciones. El raloxifeno puede causar calambres en las piernas.

Algunas mujeres que han tomado tamoxifeno o raloxifeno han tenido un derrame. Los estudios de investigación indican que la cantidad de derrames en las mujeres que toman estos medicamentos es muy similar a la cantidad en mujeres que no toman estos medicamentos. Hable con su médico o enfermera sobre su riesgo de tener un derrame.

También puede tener otros efectos secundarios graves y que pongan en peligro a su vida.

- Coágulos de sangre en los pulmones y las piernas.
  El tamoxifeno y el raloxifeno aumentan el riesgo de que se produzca un coágulo de sangre. Los coágulos de sangre son más comunes con el tamoxifeno que con el raloxifeno.
- Cáncer endometrial (cáncer en las paredes del útero).
  El tamoxifeno aumenta el riesgo de cáncer endometrial. El raloxifeno no lo aumenta.

De cada 100 mujeres que toman tamoxifeno o raloxifeno durante 5 años, el medicamento causará un coágulo de sangre o cáncer endometrial en aproximadamente 1 mujer.

Tomar raloxifeno o tamoxifeno reduce el riesgo en la mujer de algunos tipos de cáncer del seno. Algunas mujeres que toman estos medicamentos tendrán cáncer del seno de todos modos.

El tomar estos medicamentos no reduce el riesgo de muerte por cáncer del seno. Tampoco significa que una mujer vivirá más. Aún no está claro por qué esto es así. Puede deberse a que los medicamentos reducen los tipos de cáncer del seno que son más fáciles de tratar.

## Piense sobre la decisión

La mayoría de las mujeres jamás tendrá cáncer del seno. Sin embargo, algunas mujeres tienen un riesgo más alto que otras. Hable con su médico o enfermera sobre su riesgo de tener cáncer del seno.

El tamoxifeno y el raloxifeno pueden reducir su riesgo de tener ciertos tipos de cáncer del seno. Estos medicamentos pueden también aumentar su riesgo de tener problemas graves. Hable con su médico o enfermera sobre su riesgo de tener problemas graves a causa de estos medicamentos.

Piense sobre estas preguntas.

- ¿Tengo un riesgo alto o bajo de tener cáncer del seno? ¿Tengo un riesgo alto o bajo de tener problemas graves por el medicamento?
  El riesgo de efectos secundarios no debería ser más alto que el beneficio de los medicamentos.
- ¿Puedo ser constante?
  Estos medicamentos deben ser tomados todos los días durante no más de 5 años. Pueden causar sofocos con frecuencia.
- ¿Afecta el costo de los medicamentos mi decisión?

El costo de los medicamentos puede ser importante para usted. Necesitan ser tomados por un largo tiempo, por lo que el costo puede aumentar. Averigüe si su seguro cubre el uso de estos medicamentos para reducir el riesgo de cáncer del seno. El gráfico siguiente le da una idea del costo.

Precio del raloxifeno y del tamoxifeno

Nombre del medicamento | Nombre comercial | Dosis^1^ | Con qué frecuencia, por cuánto tiempo | Cómo se toma | Precio por mes^2^
Nombre del medicamento | Nombre comercial | Dosis^1^ | Con qué frecuencia, por cuánto tiempo | Cómo se toma | Nombre genérico
Raloxifeno | Evista® | 60 mg | Una vez al día^3^ | Comprimido | ND | $115
Tamoxifeno | Nolvadex® | 20 mg | Una vez al día por 5 años | Comprimido | $115 | $245

1 Las dosis son para reducir el riesgo de contraer cáncer del seno.

2 Precio de venta promedio según el Red Book, 2009.

3 No se sabe aún por cuánto tiempo se debe tomar el raloxifeno para prevenir el cáncer del seno.

ND = no disponible en forma genérica.

## Preguntas para su médico o enfermera

- ¿Cuál es mi riesgo de contraer cáncer del seno? ¿Mi riesgo es mayor o menor al de otras mujeres de mi edad?
- ¿Qué pasa si no quiero empezar a medicarme a la edad que tengo ahora? ¿Puedo tomar la decisión de comenzar más adelante?
- ¿Mi riesgo de que se produzcan coágulos de sangre es más alto que lo normal?
- ¿Es alguno de estos medicamentos una mejor opción para mí? ¿Por qué?
- ¿Cómo se pueden disminuir los efectos secundarios como los sofocos?
- ¿Hay algo más que pueda hacer para reducir mi riesgo de contraer cáncer del seno?

## ¿Dónde puede obtener más información?

Visite www.effectivehealthcare.ahrq.gov.

Pulse en la guías para pacientes y consumidores si desea imprimir una copia y aprender sobre otras condiciones.

Si desea ejemplares impresos gratuitos de esta guía, llame al 800-358-9295. Pida a la AHRQ Publications Clearinghouse la Publicación AHRQ Número 10-EHC028-B.

Para aprender más sobre el cáncer del seno, visite la página web de MedlinePlus: http://www.nlm.nih.gov/medlineplus/spanish/breastcancer.html.

Si desea más información sobre la prevención del cáncer del seno, visite la página web del Instituto Nacional del Cáncer: http://www.cancer.gov/espanol/tipos/seno.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 123 informes de investigación. La revisión se titula Comparative Effectiveness of Medications to Reduce the Risk of Primary Breast Cancer in Women (Comparación de la efectividad de medicamentos para reducir el riesgo de contraer cáncer del seno primario en mujeres) (2009) y fue escrita por el Oregon Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Oregon).

## Related Content

Research Review

Clinician Guide

Consumer Guide