# Reducción del riesgo de fracturas de huesos

Revisión de las investigaciones para adultos con baja densidad ósea

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Su médico^*^ ha dicho que usted tiene baja densidad ósea (de los huesos). Las personas con baja densidad ósea tienen una de dos condiciones:
  - Osteopenia: baja densidad ósea leve
  - Osteoporosis: baja densidad ósea severa
- Su médico le ha dicho que puede tener mayor riesgo de fracturarse un hueso debido a su baja densidad ósea.
- Usted se fracturó un hueso porque se cayó mientras estaba de pie.
- Su médico le ha sugerido medicamentos para disminuir el riesgo de fracturarse un hueso.

### No, esta información no es apropiada para usted si

- Su médico no ha dicho que usted tenga baja densidad ósea o que necesite medicamentos para disminuir su riesgo de fracturarse los huesos.
- Usted tiene menos de 18 años. Esta investigación se realizó en adultos.

### ¿Qué cubre este resumen?

Este resumen explica cómo la baja densidad ósea puede aumentar el riesgo de fracturarse un hueso y lo que las investigaciones han descubierto acerca de diferentes tratamientos para disminuir el riesgo. Puede ayudarle a hablar con su médico sobre el tratamiento que podría ser apropiado para usted.

## ¿De dónde proviene la información de este resumen?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 567 estudios publicados entre enero 2005 y marzo de 2011 acerca de tratamientos para la baja densidad ósea (de los huesos). El informe fue revisado por clínicos, investigadores, expertos y público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/lbd.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la baja densidad ósea?

La baja densidad ósea es una condición que ocurre cuando el tejido interior de los huesos comienza a debilitarse o se vuelve menos denso. Existen dos formas de esta condición: osteopenia (baja densidad ósea leve) y osteoporosis (baja densidad ósea severa).

#### ¿Qué causa la baja densidad ósea?

Los huesos están hechos de tejido vivo que nunca deja de crecer. Las capas de tejido de los huesos están en constante renovación. El cuerpo desintegra y elimina el tejido óseo viejo y forma tejido óseo nuevo para remplazarlo.

En las personas jóvenes, el hueso nuevo sustituye rápidamente al hueso viejo. De ese modo, sus huesos se mantienen sólidos y fuertes. A medida que avanzamos en edad, el cuerpo pierde tejido óseo con mayor rapidez de lo que puede remplazarlo. Cuando sucede esto, los huesos se debilitan y pierden solidez.

En la mayoría de las personas, los huesos se debilitan con la edad. El que una persona tenga o no osteopenia u osteoporosis depende de cuánta densidad ósea se haya perdido.

Densidad ósea normal

Baja densidad ósea

#### ¿Qué tan común es la baja densidad ósea?

- Cerca de 52 millones de personas en Estados Unidos padecen de osteoporosis o baja densidad ósea.
- Tanto hombres como mujeres pueden tener baja densidad ósea.
- La osteoporosis es más común en las mujeres, especialmente las que ya pasaron la menopausia. En Estados Unidos, aproximadamente 1 de cada 5 mujeres mayores de 50 años tiene osteoporosis.

#### ¿Cómo conozco el riesgo de fracturarme un hueso?

Es posible que su médico haya usado una gammagrafía ósea (un tipo especial de radiografía) o le haya hablado de la “Herramienta para evaluar el riesgo de fracturas” (Fracture Risk Assessment Tool, FRAX^®^) de la Organización Mundial de la Salud, para estimar el riesgo de fracturarse un hueso.

Aproximadamente 1 de cada 2 mujeres mayores de 50 años y uno de cada cinco hombres se fracturarán un hueso debido osteoporosis durante el transcurso de su vida.

#### ¿Quién corre mayor riesgo de sufrir una fractura?

El riesgo de sufrir una fractura es mayor en las mujeres, especialmente las que han pasado la menopausia o las mujeres jóvenes cuyos ovarios no funcionan.

El riesgo de fracturarse un hueso también es más alto en personas con:

- Edad avanzada.
- Antecedente de fractura de huesos por caídas.
- Origen caucásico (raza blanca).
- Artritis reumatoide.
- Antecedente de consumo de tabaco.
- Consumo de bebidas alcohólicas.
- Niveles bajos de vitamina D.
- Consumo insuficiente de calcio en los alimentos.
- Mayor riesgo de caídas, por equilibrio deficiente u otras causas.
- Condiciones que requieren medicamentos como la prednisona u otros esteroides, diluyentes de la sangre, anticonvulsivos o medicamentos contra el cáncer de seno o de próstata.

#### ¿Por qué son peligrosas las fracturas de huesos?

Las fracturas pueden causar problemas de salud graves:

- Los huesos que se fracturan con mayor frecuencia son los de la cadera, la muñeca y la columna vertebral (espina dorsal).
- Las fracturas pueden causar dolor constante y dificultar las actividades diarias.
- Los huesos de la columna vertebral pueden comprimirse entre sí y causar dolor. En estos casos, la persona puede perder hasta una pulgada o más de estatura.
- Mientras se recupera de una fractura, especialmente de la cadera, es posible que necesite cuidado constante y que tenga que permanecer en un hogar de ancianos.
- Si se fractura la cadera, probablemente se necesitará cirugía para repararla. La cirugía aumenta el riesgo de que ocurran otros problemas de salud.
- Una vez que se fractura un hueso, es posible que aumente la probabilidad de que se fracturen otros, lo que puede originar más problemas de salud.

Aproximadamente 1 de cada 5 mujeres mayores de 50 años que se fracturan la cadera morirán en el transcurso de un año.

## Conozca sus opciones

### ¿Qué tratamientos pueden ayudar a reducir el riesgo de sufrir una fractura?

Para las personas con baja densidad ósea, hay tratamientos que pueden ayudar a fortalecer los huesos y disminuir el riesgo de fractura. Su médico puede recomendar uno o más de los tratamientos siguientes:

- Medicamentos
- Suplementos alimenticios
- Ejercicio

### ¿Qué medicamentos existen?

Los medicamentos que ayudan a reducir el riesgo de fractura ayudan a retardar la degradación del hueso viejo o ayudan a formar más rápidamente el hueso nuevo.

- La mayor parte de las investigaciones se han hecho para ver qué tan bien funcionan estos medicamentos en las mujeres con osteoporosis que ya pasaron la menopausia. No se han hecho tantos estudios para ver si estos medicamentos funcionan en los hombres o en las mujeres que no han pasado la menopausia.
- Algunos de estos medicamentos los pueden tomar también las personas con osteopenia.
- No existe suficiente investigación para saber exactamente cuánto reducirán los medicamentos el riesgo de fracturarse un hueso.
- Aun cuando su densidad ósea no cambie mientras toma el medicamento, eso no significa que el medicamento no esté funcionando para protegerlo contra las fracturas.

#### Medicamentos y los huesos que protegen

Respecto a las mujeres con osteoporosis que ya pasaron la menopausia, los investigadores encontraron que los medicamentos siguientes reducen o no reducen el riesgo de fracturarse los huesos que se mencionan.

Medicamentos | | Columna vertebral | Cadera | Muñeca | Otro(s) hueso(s)
Bisfosfonatos | Alendronato (Fosamax^®^) | ☑ | ☑ | ☑^*^ | ☑
Bisfosfonatos | Ibandronato (Boniva^®^) | ☑ | — | — | —
Bisfosfonatos | Risedronato (Actonel^®^ o Atelvia^®^) | ☑ | ☑ | ☑^*^ | ☑
Bisfosfonatos | Ácido zoledrónico (Reclast^®^) | ☑ | — | — | ☑
Denosumab (Prolia^®^) | | ☑ | ☑ | — | ☑
Terapia hormonal para la menopausia (MHT, por su sigla en inglés)^**^ | | ☒ | ☒ | ☒ | ☒
Raloxifeno (Evista^®^) | | ☑ | ☒ | ☒ | ☒
Teriparatida (Forteo^®^) | | ☑ | — | — | ☑

☑= reduce el riesgo;

☒= NO reduce el riesgo;

— = se desconoce.

* Estos medicamentos parecen disminuir el riesgo de fracturarse un hueso de la muñeca, pero no existe suficiente investigación para saberlo con certeza.

** En las mujeres que ya pasaron la menopausia pero NO tienen osteoporosis, la MHT disminuye el riesgo de que se fracture la columna vertebral, la cadera u otros huesos.

#### ¿Cuánto tiempo protegerá el medicamento mis huesos?

No existe suficiente investigación para saber cuánto tiempo pueden proteger de fracturas la mayoría de los medicamentos, ni cuánto tiempo puede ser necesario que tome usted un medicamento. Existe cierta evidencia de que el uso de alendronato (Fosamax^®^) por más de 5 años puede proteger de fracturas la columna vertebral. Algunas mujeres pueden experimentar protección de otros huesos, diferentes de la columna vertebral, después de tomar este medicamento durante 5 años, mientras que otras mujeres no. Solamente las mujeres que aún tienen osteoporosis o fracturas de la columna después de los primeros 5 años de tratamiento pueden obtener protección para huesos distintos de la columna si toman el medicamento por otros 5 años.

#### Bisfosfonatos

Los bisfosfonatos son un grupo de medicamentos que retrasan la degradación de los huesos.

Nombre del medicamento | Nombre comercial | Cómo se administra
Alendronato | Fosamax^®^ | - Una pastilla cada día; - Una pastilla una vez a la semana
Ibandronato | Boniva^®^ | - Una pastilla al día o una vez al mes; - Por vía intravenosa (por medio de un tubo y una aguja en la vena), una vez cada 3 meses
Risedronato | Actonel^®^ o Atelvia^®^ | - Una pastilla cada día, una vez a la semana o una vez al mes
Ácido zoledrónico | Reclast^®^ | - Por un acceso intravenoso una vez al año o una vez cada dos años

- En el caso del alendronato (Fosamax^®^), el ibandronato (Boniva^®^) y el risedronato (Actonel^®^), la pastilla se debe tomar con un vaso de agua completo teniendo el estómago vacío. Además, se debe estar de pie y no acostarse por un mínimo de 30 minutos después de tomar alguno de esos medicamentos.
- A diferencia de otras pastillas de bisfosfonato, Atelvia^®^ debe tomarse con alimentos y por lo general se toma inmediatamente después del desayuno.

#### Los investigadores encontraron

- Para mujeres con osteoporosis que ya pasaron la menopausia:
  - El alendronato (Fosamax^®^) disminuye el riesgo de fracturarse la columna vertebral, la cadera u otros huesos. Este medicamento también puede proteger la muñeca, pero no existe suficiente investigación para poder afirmarlo con certeza.
  - El ibandronato (Boniva^®^) disminuye el riesgo de fracturarse la columna vertebral.
  - El risedronato (Actonel^®^ o Atelvia^®^) disminuye el riesgo de fracturarse la columna vertebral, la cadera u otros huesos. Este medicamento también puede proteger la muñeca, pero no existe suficiente investigación para poder afirmarlo con certeza.
  - El ácido zoledrónico (Reclast^®^) disminuye el riesgo de fracturarse la columna vertebral, la cadera u otros huesos.
- Si usted no sigue las instrucciones de su médico para tomar bisfosfonatos, aumentará su riesgo de fracturase un hueso.
- Algunos medicamentos deben tomarse una vez a la semana (en vez de una vez al día). Otros se toman solamente una vez al mes o una vez al año.
  - A muchas personas les es más fácil tomar estos medicamentos una vez a la semana.
  - No existe suficiente investigación para saber si a la gente le resulta más fácil tomar los medicamentos una vez al mes.
  - Los efectos secundarios podrían ser diferentes entre los medicamentos que se administran una vez a la semana y una vez al mes.
- No existe suficiente investigación para saber si algún bisfosfonato funciona mejor que otros.

#### Denosumab (Prolia^®^)

- El denosumab es un medicamento que retarda la degradación de los huesos.
- Este medicamento es para mujeres que han pasado la menopausia, para hombres, y para mujeres que reciben tratamiento por algunos tipos de cáncer.
- Se administra en forma de inyección en el consultorio médico, cada 6 meses.

##### ¿Qué dicen las investigaciones acerca del denosumab (Prolia^®^)?

Los investigadores encontraron que el denosumab disminuye el riesgo de fracturarse la columna vertebral, la cadera u otros huesos, en las mujeres con osteoporosis que ya pasaron la menopausia.

#### Raloxifeno (Evista^®^)

- El raloxifeno es otro medicamento que retarda la degradación de los huesos.
- Este medicamento es solamente para mujeres que ya pasaron la menopausia.
- El raloxifeno no es una hormona, pero evita que los huesos se degraden, como lo hace la hormona femenina natural llamada estrógeno.
- El raloxifeno es una pastilla que por lo general se toma una vez al día, con o sin alimentos. Esta pastilla se debe tomar aproximadamente a la misma hora cada día.

##### ¿Qué dicen las investigaciones acerca del raloxifeno (Evista^®^)?

Los investigadores encontraron:

- El raloxifeno disminuye el riesgo de que se fracture la columna vertebral en las mujeres con osteoporosis que ya pasaron la menopausia.
- El raloxifeno NO disminuye el riesgo de sufrir fracturas de la cadera, la muñeca u otros huesos en las mujeres con osteoporosis que ya pasaron la menopausia.

#### Teriparatida (Forteo^®^)

- La teriparatida es un medicamento que actúa como una hormona natural. Ayuda al organismo a generar hueso nuevo.
- Este medicamento es para mujeres que ya pasaron la menopausia y para hombres.
- Es una inyección para administración diaria que viene en una “pluma”, un dispositivo con el que el paciente se inyecta el medicamento en el abdomen o el muslo.

##### ¿Qué dicen las investigaciones acerca de la teriparatida (Forteo^®^)?

Los investigadores encontraron que la teriparatida disminuye el riesgo de fracturas de la columna vertebral y otros huesos en mujeres con osteoporosis que ya pasaron la menopausia.

#### Terapia hormonal para la menopausia (MHT, por su sigla en inglés)

- La MHT es un tratamiento en el que las mujeres toman suplementos hormonales. Para este tratamiento, los médicos usan estrógeno, ya sea solo o con progestina.
- Este tratamiento es solamente para mujeres que ya pasaron la menopausia.
- La MHT puede tener efectos secundarios graves. Puede aumentar el riesgo de sufrir un derrame cerebral, enfermedades del corazón y cáncer del seno.
- Debido al riesgo de efectos secundarios graves, muchos profesionales de salud ya no recomiendan tomar estrógeno con progestina para prevenir la osteoporosis.

##### ¿Qué dicen las investigaciones sobre la MHT?

Los investigadores encontraron:

- La MHT no disminuye el riesgo de fracturarse un hueso en las mujeres con osteoporosis que ya pasaron la menopausia.
- En las mujeres que ya pasaron la menopausia pero NO tienen osteoporosis, la MHT ayuda a evitar fracturas en la columna vertebral, la cadera y otros huesos.

### ¿Cuáles son los efectos secundarios posibles de estos medicamentos?

Medicamentos | Posibles efectos secundarios^*^ | Información adicional
Todos los bisfosfonatos:; - Alendronato (Fosamax^®^); - Ibandronato (Boniva^®^); - Risedronato (Actonel^®^ o Atelvia^®^); - Ácido zoledrónico (Reclast^®^) | Náusea, vómito, acidez estomacal o irritación del esófago (el tubo que lleva el alimento de la boca al estómago) | Seguir las instrucciones para tomar estos medicamentos disminuye el riesgo de tener estos efectos secundarios.
Todos los bisfosfonatos:; - Alendronato (Fosamax^®^); - Ibandronato (Boniva^®^); - Risedronato (Actonel^®^ o Atelvia^®^); - Ácido zoledrónico (Reclast^®^) | Niveles bajos de calcio en la sangre | Este efecto secundario es fácil de tratar tomando suplementos de calcio.
Todos los bisfosfonatos:; - Alendronato (Fosamax^®^); - Ibandronato (Boniva^®^); - Risedronato (Actonel^®^ o Atelvia^®^); - Ácido zoledrónico (Reclast^®^) | Fractura de un hueso del muslo | Según pocas investigaciones, el uso de estos medicamentos por más de 5 años puede aumentar el riesgo de fracturarse un hueso del muslo, pero no existe la investigación suficiente para confirmar con certeza. Este efecto secundario es raro.
Todos los bisfosfonatos:; - Alendronato (Fosamax^®^); - Ibandronato (Boniva^®^); - Risedronato (Actonel^®^ o Atelvia^®^); - Ácido zoledrónico (Reclast^®^) | Dolor de huesos, articulaciones o músculos | Avise a su médico si este efecto secundario le impide hacer ejercicio o disfrutar de sus actividades favoritas.
Todos los bisfosfonatos:; - Alendronato (Fosamax^®^); - Ibandronato (Boniva^®^); - Risedronato (Actonel^®^ o Atelvia^®^); - Ácido zoledrónico (Reclast^®^) | Problemas con la salud de su hueso mandibular (quijada) | Las investigaciones encontraron que el uso de estos medicamentos puede aumentar el riesgo de tener problemas en el hueso de la mandíbula. Es un efecto secundario raro, pero es serio y puede causar dolor, infecciones y úlceras en la boca. En estudios de investigación, la mayoría de los pacientes que experimentaron este efecto secundario estaban recibiendo tratamiento para el cáncer.
Ácido zoledrónico (Reclast^®^) | Problemas del riñón, incluida la insuficiencia renal | Mientras usted toma este medicamento, su médico puede realizar exámenes de sangre o de orina para detectar este efecto secundario.
Denosumab (Prolia^®^) | Náusea, vómito, acidez estomacal o irritación del esófago | Seguir las instrucciones para tomar estos medicamentos disminuye el riesgo de tener estos efectos secundarios.
Denosumab (Prolia^®^) | Niveles bajos de calcio en la sangre. | Este efecto secundario es fácil de tratar.
Denosumab (Prolia^®^) | Erupciones o salpullido | Llame a su médico si tiene salpullido o ampollas que no desaparecen o que empeoran.
Denosumab (Prolia^®^) | Mayor riesgo de infección | Las infecciones pueden ser graves, y en ciertos casos, afectar su corazón. Pero el riesgo de este efecto secundario es bajo.
Denosumab (Prolia^®^) | Problemas con la salud del hueso mandibular (quijada) | Es un efecto secundario raro, pero es serio y puede causar dolor, infecciones y úlceras en la boca.
Terapia hormonal en la menopausia (MHT, por su sigla en inglés) | Enfermedades del corazón | Uno de los estudios encontró que el riesgo puede ser más alto durante el primer año de estar tomando este medicamento.
Terapia hormonal en la menopausia (MHT, por su sigla en inglés) | Derrame | Es importante conocer los síntomas de un derrame cerebral y buscar atención médica inmediata.
Terapia hormonal en la menopausia (MHT, por su sigla en inglés) | Cáncer del seno | El uso de una combinación de las hormonas estrógeno y progestina puede ocasionar un cáncer del seno más invasivo y un mayor riesgo de muerte por cáncer del seno.
Raloxifeno (Evista^®^) | Dolor del brazo o de la pierna, dolor muscular o calambres | Avise a su médico si este efecto secundario le impide hacer ejercicio o disfrutar de sus actividades favoritas.
Raloxifeno (Evista^®^) | Sofocos o calores | Este efecto secundario puede ser molesto o incómodo, pero no causa ningún otro riesgo de salud.
Raloxifeno (Evista^®^) | Coágulos de sangre | El uso de este medicamento puede aumentar el riesgo de que se formen coágulos en las piernas o los pulmones. Si la persona no podrá moverse durante 3 días o más (porque está enferma o recuperándose de cirugía) deberá preguntar al médico si debe interrumpir el medicamento.
Teriparatida (Forteo^®^) | Dolores de cabeza | Aunque este efecto secundario puede tratarse con aspirina u otros analgésicos, se deberá consultar al médico si los dolores de cabeza se vuelvan demasiado fuertes o si son muy frecuentes.
Teriparatida (Forteo^®^) | Niveles altos de calcio en la sangre | Este efecto secundario puede tratarse con medicamentos.
Teriparatida (Forteo^®^) | Mayor riesgo de cáncer de los huesos | Este efecto secundario se produjo con dosis más altas de las que suelen tomar las personas.

* Esta lista proviene de estudios de investigación y de la Food and Drug Administration (Administración de Alimentos y Medicamentos de Estados Unidos; FDA, por su sigla en inglés).

### ¿Me ayudan los suplementos alimenticios a mantener mis huesos sanos?

Su médico puede recomendarle que tome calcio y vitamina D, ya sea solos o junto con sus medicamentos con receta, para ayudar a fortalecer sus huesos y a reducir su riesgo de desarrollar osteoporosis. Los investigadores no están seguros si el uso de calcio o vitamina D sin otro tratamiento reduce el riesgo de fractura de huesos en las personas con osteoporosis.

Su cuerpo necesita calcio para formar los huesos, y la vitamina D ayuda al cuerpo a utilizar el calcio. La cantidad de calcio y de vitamina D que necesita usted cada día depende de su edad.

Es importante asegurarse de que su dieta sea rica en calcio y vitamina D. El calcio y la vitamina D pueden obtenerse de muchos alimentos. Su médico pueden recomendarle comprar pastillas (con o sin receta) que contienen calcio y vitamina D. Hable con su médico sobre la cantidad de calcio y vitamina D que es apropiada para usted.

Algunas fuentes de calcio son:

- Los productos lácteos, como la leche, el queso y el yogur.
- Las verduras de hojas verde oscuro, como el brócoli y la col rizada.
- El pan, las pastas, los cereales y el arroz contienen cantidades bajas de calcio.
- Alimentos “fortificados” con calcio (que lo llevan agregado), como muchos jugos de frutas, tofu (queso de soja o soya) y cereales.

Algunas fuentes de vitamina D son:

- Los pescados ricos en grasas, como el salmón, el atún y la caballa o sierra.
- Vegetales de hojas verdes.
- El hígado de res y la yema de huevo proporcionan cantidades pequeñas de vitamina D.
- Los alimentos fortificados con vitamina D, como la leche, los cereales, algunos jugos de frutas y el yogur.
- Luz solar.

También puede haber demasiada vitamina D en el cuerpo. El exceso de vitamina D puede dañar el hígado.

Los signos de que usted ha tomado demasiada vitamina D incluyen:

- Náusea, vómito, falta de apetito, estreñimiento, debilidad o pérdida de peso.
- Confusión, desorientación o latido cardiaco irregular.

### ¿El ejercicio puede ayudar?

Su médico puede también recomendar ejercicios para ayudar a fortalecer los huesos, a mejorar el equilibrio y a reducir el riesgo de caídas.

- En los ejercicios donde se “carga peso”, se aumenta el peso y la gravedad para fortalecer los huesos.
- Ejercicios donde se carga peso incluyen: caminar, levantar pesas y subir escaleras.
- Algunos ejercicios pueden ser demasiado fuertes para los huesos y aumentar el riesgo de fractura. Por ejemplo, actividades como el golf obligan a torcer el cuerpo, de maneras que pueden ser peligrosas.
- Hable con su médico sobre cuáles ejercicios son mejores para usted.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Para las mujeres que ya pasaron la menopausia, existe ayuda en Internet para tomar decisiones. La herramienta de Internet:

- Ayuda a calcular su riesgo de fracturarse un hueso.
- Proporciona información detallada sobre los medicamentos que se usan para prevenir fracturas.
- Le permite imprimir información y preguntas para llevarlas a su médico.

La herramienta de Internet está disponible en www.effectivehealthcare.ahrq.gov/lbddecisionaid.cfm (disponible sólo en inglés).

Solamente usted y su médico pueden decidir si la capacidad de algún medicamento para mejorar su condición compensa el riesgo de un efecto secundario grave. Cada persona responde de manera diferente a distintos medicamentos. Su médico puede poner a prueba varios medicamentos antes de encontrar el correcto.

Al decidir qué tratamiento sería el mejor para usted, se deben considerar varias cosas:

- En caso de osteopenia (baja densidad ósea leve), si ya necesita empezar a tomar medicamentos o si puede esperar y observar si su condición empeora.
- La prueba de densidad ósea indica el riesgo que tiene de fracturase un hueso.
- Los beneficios y los efectos secundarios de cada tratamiento.
- En qué formas el médico puede ayudarle a descubrir los efectos secundarios, para poder tratarlos o cambiar de medicamento.
- Qué medicamento se ajusta mejor a su vida diaria y su rutina.
- Los costos directos (desembolso) de cada opción de tratamiento, y si los medicamentos existen en forma genérica.

#### ¿Cuáles son los costos del tratamiento?

Los precios de mayoreo de los medicamentos con receta para tratar la osteoporosis se presentan abajo. Los precios de mayoreo son los precios que pagan las farmacias. Estos precios se dan aquí para que pueda usted comparar el costo de los distintos medicamentos. El costo que tengan para usted estos medicamentos dependerá de su seguro médico, la dosis (cantidad) que necesite y si el medicamento existe en forma genérica.

#### Precios de mayoreo de medicamentos con receta para la osteoporosis

Nombre del medicamento | Dosis | Forma | Cada cuánto | Precio del genérico por mes^*^ | Nombre comercial | Precio del de nombre comercial por mes^*^
Bisfosfonatos
Alendronato | 10 mg | Tableta | Una vez al día | $88 | Fosamax^®^ | $100
| 70 mg | Tableta | Una vez a la semana | $82 | Fosamax^®^ | $103
| 70 mg | Líquido | Una vez a la semana | ND | Fosamax^®^ | $107
Ibandronato | 150 mg | Tableta | Una vez al mes | $111 | Boniva^®^ | $154
| 3 mg | IV | Una vez cada 3 meses | ND | Boniva^®^ | $316
Risedronato | 5 mg | Tableta | Una vez al día | ND | Actonel^®^; Atelvia^®^ | $142; ND
| 35 mg | Tableta | Una vez a la semana | ND | Actonel^®^; Atelvia^®^ | $132; $132
| 150 mg | Tableta | Una vez al mes | ND | Actonel^®^; Atelvia^®^ | $143; ND
Ácido zoledrónico | 5 mg | IV | Una vez al año | ND | Reclast^®^ | $1,288
Otros
Denosumab | 60 mg | Inyección | Una vez cada 6 meses | ND | Prolia^®^ | $990
Raloxifeno | 60 mg | Tableta | Una vez al día | ND | Evista^®^ | $166
Teriparatida | 20 μg (mcg) | Pluma de inyección | Una vez al día | ND | Forteo^®^ | $1,313

* Los precios son el promedio de venta al mayoreo según el RED BOOK Online^®^. Los precios del medicamento genérico son un valor medio entre los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = no disponible

#### Pregunte a su médico

- ¿Qué riesgo tengo de sufrir una fractura?
- ¿Cuáles son las razones por las que escogió recetarme este medicamento en particular?
- ¿Cómo tomo este medicamento? ¿Debo tomarlo diariamente, cada semana, cada mes o una vez al año?
- ¿Por cuánto tiempo necesitaré tomar este medicamento?
- ¿Qué efectos secundarios puede ocasionar este medicamento?
- ¿Necesito tomar un suplemento de calcio y vitamina D?
- ¿Qué tipos de ejercicio son los mejores para mí y qué tipos de ejercicio debo evitar?

Otras preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis: An Update to the 2007 Report (Tratamientos para prevenir fracturas en hombres y mujeres con densidad ósea baja u osteoporosis: actualización del informe de 2007), de marzo de 2012.

El informe fue producido por el Southern California Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Sur de California), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/lbd.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes con baja densidad ósea.

Traducido de la publicación en inglés titulada Reducing the Risk of Bone Fracture: A Review of the Research for Adults With Low Bone Density

* En este resumen, el término “médico” se refiere a los profesionales de la atención médica que pueden atenderlo, lo que incluye a su médico, enfermera o asistente médico.