# Tratamientos para la osteoporosis que ayudan a prevenir fracturas de huesos

Guía para mujeres después de la menopausia

## Hechos resumidos

- Los medicamentos para tratar la osteoporosis pueden reducir el riesgo de las fracturas de los huesos.
- Todos los medicamentos incluidos en esta guía pueden prevenir fracturas de los huesos pequeños de la columna vertebral.
- Algunos de los medicamentos incluidos también previenen fracturas de la cadera o de la muñeca.
- Existen tres distintos tipos de medicamentos para tratar la osteoporosis. Cada tipo de medicamento tiene distintos riesgos.
- Para conservar la salud de sus huesos, las mujeres necesitan ingerir suficiente calcio y vitamina D, especialmente después de la menopausia.
- Las caídas pueden causar fracturas de los huesos. El ejercicio puede ayudar a evitar las caídas. Además es bueno para mejorar la salud de los huesos, la fuerza muscular, y el equilibrio.

## ¿Qué cubre esta guía?

La osteoporosis es la pérdida de la densidad (o solidez) de los huesos. Cuando pierden densidad, los huesos se debilitan y tienden a fracturarse más fácilmente. Si le diagnosticaron osteoporosis, esta guía le será útil. Explica las formas de evitar las fracturas de los huesos ocasionadas por la osteoporosis. Le ayudará a hablar con su médico o enfermera sobre cómo reducir el riesgo de fracturas de huesos. Se tratan los siguientes temas en esta guía:

- Distintos tipos de tratamientos para prevenir las fracturas de los huesos por osteoporosis.
- Qué tan eficientes son estos tratamientos.
- Efectos secundarios de los medicamentos contra la osteoporosis.
- Costo de los medicamentos.

La información en esta guía proviene de una revisión, financiada por el gobierno, de informes de investigación sobre los tratamientos de la osteoporosis para prevenir las fracturas de los huesos.

## ¿Qué no cubre esta guía?

Esta guía no incluye tratamientos para la osteoporosis en mujeres premenopáusicas ni en los hombres. Tampoco cubre formas de prevenir la osteoporosis. Sin embargo, los medicamentos en esta guía pueden ayudar a restaurar los huesos o a retrasar el deterioro de los huesos viejos.

## Aprenda sobre la osteoporosis

### ¿Qué es la osteoporosis?

La osteoporosis consiste en una pérdida de la densidad o solidez de los huesos. Cuando pierden densidad, los huesos se vuelven débiles y más fáciles de quebrar. Se dice que hay osteoporosis cuando los huesos han perdido tanta densidad que se quiebran fácilmente.

### ¿En quiénes se presenta la osteoporosis?

Cerca de la mitad de las mujeres de 50 años en adelante tendrán una fractura por osteoporosis en algún momento de la vida.

La osteoporosis es más frecuente en:

- Las mujeres después de la menopausia, sobre todo porque el cuerpo produce menos estrógeno.
- Las mujeres más pequeñas y delgadas.
- Las mujeres de raza blanca o de origen asiático.
- Las mujeres que tienen familiares que han padecido de osteoporosis y se han fracturado un hueso.
- Las mujeres que fuman o beben alcohol en exceso.
- Las mujeres que toman ciertos medicamentos, como los que se usan para tratar enfermedades de la tiroides o los esteroides.

La osteoporosis puede presentarse tanto en mujeres como en hombres, pero la mayor parte de la investigación se concentra en las mujeres.

### ¿Cuáles son las causas de la osteoporosis?

El hueso es un tejido vivo. El hueso viejo y dañado se deteriora y es sustituido constantemente por hueso nuevo. Al aumentar la edad, el cuerpo pierde minerales, como el calcio. Este mineral es necesario para la formación de hueso nuevo. Si tiene osteoporosis, significa que su hueso viejo no se está reemplazando con hueso nuevo con la rapidez necesaria.

Las hormonas corporales, como el estrógeno, ayudan a evitar que el hueso se deteriore demasiado pronto. Al llegar a la menopausia, el cuerpo de la mujer empieza a producir menos estrógeno. Esa reducción de las hormonas explica por qué el riesgo de osteoporosis en la mujer aumenta después de la menopausia.

### ¿Cómo sabe si tiene osteoporosis?

Para saber si tiene la osteoporosis, su médico le hará una prueba de la densidad ósea. A menudo se trata de una radiografía especial, conocida como DXA (por sus siglas en inglés), que mide el grosor de sus huesos. Puede indicar si sus huesos se están debilitando. No predice con certeza si van a ocurrir fracturas de huesos. Su médico o enfermera podrán decirle si la densidad de sus huesos es baja e indica que existe osteoporosis.

Imágenes de huesos usadas con permiso de la Fundación Internacional de la Osteoporosis

## ¿Qué huesos pueden romperse?

La osteoporosis puede ocasionar que se quiebre cualquier hueso. Los más propensos a quebrarse son los huesos de la columna vertebral, la cadera, y la muñeca. Los huesos pueden quebrarse por una caída o incluso por un golpe fuerte.

### Columna vertebral

Las grietas en la columna vertebral pueden causar que éstas se aplasten entre sí (fractura por compresión), lo cual puede ocasionar molestias en la espalda y dolor. De hecho, una pérdida de estatura de 1 pulgada (2.5 cm) o más puede ser el primer signo de osteoporosis.

### Cadera

La fractura de cadera casi siempre debe repararse con cirugía. La recuperación de la operación puede llevar mucho tiempo. La fractura de cadera puede aumentar el riesgo de problemas graves, incluso la muerte.

### Muñeca

La fractura de muñeca dificulta el uso del brazo y la mano. Puede también requerir cirugía.

## Aprenda sobre huesos sanos

El Cirujano General de Estados Unidos afirma que el calcio, la vitamina D, y el ejercicio son importantes para mantener los huesos sanos. También advierte que el hábito de fumar y el consumo excesivo de alcohol aumentan el riesgo de fracturas de los huesos.

### Calcio y vitamina D

Muchas personas no toman suficiente calcio y vitamina D. El calcio es el componente básico de los huesos. La vitamina D ayuda a que los huesos utilicen el calcio. Las dos sustancias trabajan juntas para formar los huesos.

#### Calcio

Las mujeres necesitan más calcio después de la menopausia. Cada día debe ingerir por lo menos:

- 1200 mg de calcio.

Las pastillas de calcio pueden ayudarle a alcanzar esta meta. Lo mejor es tomar dosis pequeñas, de 500 mg o menos, con las comidas.

#### Vitamina D

La necesidad de vitamina D varía según la edad. Cada día se debe ingerir por lo menos:

- 400 IU de vitamina D, entre los 51 y 70 años.
- 600 IU de vitamina D, de los 71 años en adelante.

Muchas pastillas de calcio y multivitamínicos contienen vitamina D. Revise las etiquetas para cerciorarse.

### Ejercicio

El ejercicio es beneficioso para la salud de los huesos, la fuerza muscular, y el equilibrio. El ejercicio ayuda a reducir el riesgo de sufrir una caída. En muchas personas con osteoporosis, las caídas son la causa de las fracturas de los huesos.

## Aprenda sobre los medicamentos

Existen tres tipos de medicamentos para tratar la osteoporosis. La mayoría son pastillas. Algunos se administran por inyección bajo la piel o directamente en la vena por acceso intravenoso. Otro es un aerosol nasal. Algunos se toman una vez al día. Otros, una vez a la semana, una vez al mes, o incluso con menor frecuencia.

### Bisfosfonatos

Los medicamentos del grupo de los bisfosfonatos incluyen el alendronato (Fosamax^®^), el ibandronato (Boniva^®^), el risedronato (Actonel^®^), y el ácido zoledrónico (Reclast^®^). Se adhieren a la superficie de los huesos y retardan el deterioro del hueso viejo.

### SERM

Los moduladores selectivos del receptor de estrógeno (SERM, siglas en inglés), como el raloxifeno (Evista^®^), retardan el deterioro del hueso viejo. Aunque no son hormonas, tienen un efecto en el hueso parecido al del estrógeno.

### Hormonas

Las pastillas de estrógeno (Premarin^®^) y de estrógeno con progestina (Prempro^®^, Premphase^®^) refuerzan las hormonas naturales del cuerpo. También retardan el deterioro del hueso viejo.

La teriparatida (Forteo^®^) ayuda al cuerpo a formar hueso nuevo con mayor rapidez de lo que el viejo se deteriora.

La calcitonina (Miacalcin^®^, Fortical^®^) retarda el deterioro del hueso viejo.

## Investigación sobre los beneficios de los medicamentos

En la tabla siguiente, el símbolo ✓ indica que la investigación ha demostrado la eficacia del medicamento para prevenir las fracturas de ciertos huesos. Un signo ? significa que las investigaciones hasta este momento aún no han demostrado que el medicamento sirva para esos huesos. Actualmente, se han realizado más investigaciones sobre algunos huesos que sobre otros.

Dónde actúa el medicamento para prevenir las fracturas de los huesos

Medicamento | Nombre de la marca | Columna vertebral | Cadera y otros huesos
BISFOSFONATOS
Alendronato | Fosamax^®^ | ✓ | ✓
Ibandronato | Boniva^®^ | ✓ | ?
Risedronato | Actonel^®^ | ✓ | ✓
Ácido zoledrónico | Reclast^®^ | ✓ | ✓
SERM
Raloxifeno | Evista^®^ | ✓ | ?
HORMONAS
Estrógeno | Premarin^®^ | ✓ | ✓
Estrógeno más progestina | Prempro^®^, Premphase^®^ | ✓ | ✓
Teriparatida | Forteo^®^ | ✓ | ?
Calcitonina | Miacalcin^®^, Fortical^®^ | ✓ | ?

## Efectos secundarios de los bisfosfonatos

Todos los medicamentos incluidos en esta guía pueden causar efectos secundarios. La probabilidad de que se produzcan efectos secundarios graves con los medicamentos contra la osteoporosis puede depender de otros problemas de salud que tenga la persona. Pregunte a su médico o enfermera cuáles serían los riesgos que corre usted.

Consejos para el uso de las pastillas de bisfosfonato

Si sigue estas recomendaciones disminuirá la probabilidad de que ocurran problemas del esófago y del estómago.

- Tome su pastilla con el estómago vacío a primera hora del día.
- Tome un vaso de agua completo.
- Espere entre 30 y 60 minutos antes de recostarse o de comer.

### Problemas del esófago y el estómago

El esófago es el tubo que conecta la boca hasta el estómago. Con cualquiera de las pastillas de bisfosfonato pueden haber problemas con el esófago o estómago. Los más frecuentes son ardor de estómago, náuseas, y problemas para pasar la comida. Entre los más graves se incluyen las úlceras y el sangrado.

### Dolor

Los medicamentos a base de bisfosfonato pueden causar dolor en músculos, huesos, o articulaciones. Si siente dolor después de empezar a tomarlos, avise a su médico o enfermera. Ese dolor puede ser una reacción adversa al medicamento. Puede producirse enseguida o después de haberlo tomado mucho tiempo.

### Deterioro del hueso mandibular

Tal vez haya oído que los bisfosfonatos pueden causar deterioro de la mandíbula. Este problema poco frecuente se llama osteonecrosis. Se ha presentado principalmente en personas con cáncer que toman bisfosfonatos. Se ha observado solamente en pocas personas que toman bisfosfonatos para tratar la osteoporosis.

## Efectos secundarios de SERM y las hormonas

### Coágulos de sangre y embolia

El raloxifeno (Evista^®^) y las pastillas a base de estrógenos (Premarin^®^, Prempro^®^, Premphase^®^) aumentan el riesgo de tener coágulos en la sangre.

Las pastillas que contienen estrógeno (Premarin^®^, Prempro^®^, Premphase^®^) aumentan el riesgo de tener embolia.

### Problemas de los senos y el útero

Las pastillas de estrógeno combinadas con progestina (Prempro^®^, Premphase^®^) aumentan el riesgo de cáncer de seno.

Las pastillas que contienen estrógeno (Premarin^®^, Prempro^®^, Premphase^®^) pueden causar problemas de sangrado uterino y dolor o sensibilidad en los senos.

### Irritación nasal

La calcitonina (Miacalcin^®^, Fortical^®^), cuando se aplica en aerosol nasal, puede causar irritación de las fosas nasales.

## Cómo utilizar la información al decidir qué medicamentos tomar

Pregunte a su médico o enfermera si el medicamento es conveniente para usted. Los medicamentos para tratar la osteoporosis ayudan a prevenir las fracturas de los huesos. La mejor opción puede ser distinta para cada persona. A continuación se enumeran algunos factores que conviene considerar.

### ¿Influye la forma de administrar el medicamento en cómo se cumple con el tratamiento?

Los medicamentos incluidos en esta guía se encuentran en la forma de pastillas, aerosol nasal, inyección bajo la piel, o intravenosa. Algunos deben tomarse una vez al día. Otros se toman con menor frecuencia. Algunos vienen con instrucciones especiales.

Piense en cuál sería más conveniente para usted. Tendrá más posibilidad de prevenir fracturas si cumple cabalmente con su plan de tratamiento.

### ¿Alguna vez ha tenido una úlcera o hemorragia del estómago?

Todos los bisfosfonatos tienen algún riesgo de problemas graves del esófago y del estómago. Es posible que su médico o enfermera le recomienden un tipo diferente de medicamento si tuvo estos problemas antes.

### ¿Ha tenido coágulos de la sangre o embolia? ¿Corre riesgo de tenerlos?

Consulte a su médico sobre su riesgo de los coágulos de la sangre o embolia. Las pastillas que contienen estrógeno (Premarin^®^, Prempro^®^, y Premphase^®^) y el medicamento raloxifeno (Evista^®^) tienen mayor riesgo de que surjan problemas de este tipo.

### ¿Es el costo un factor importante para usted?

En el Dosis y costo de los medicamentos para tratar la osteoporosis y Dosis y costo de vitaminas y minerales cuadro comparar los costos de los medicamentos. Si su seguro médico incluye el surtido de recetas, verifique con ellos sobre el costo. Si necesita ayuda para pagar sus medicamentos, puede que exista un programa para usted. Partnership for Prescription Assistance (Alianza para la Ayuda con las Recetas) o PPARx en inglés, podrá informarle sobre estos programas. Página Web: www.pparx.org/es. Teléfono: 1-888-477-2669.

Dosis y costo de los medicamentos para tratar la osteoporosis

Nombre genérico^1^ | Nombre de la marca | Dosis^2^ y frecuencia de administración | Cómo se toma | Costo por mes^2^
Nombre genérico^1^ | Nombre de la marca | Dosis^2^ y frecuencia de administración | Cómo se toma | Genérico | Marca
BISFOSFONATOS
Alendronato | Fosamax^®^ | 10 mg una vez al día | Pastilla | $90 | $95
Alendronato | Fosamax^®^ | 70 mg una vez a la semana | Pastilla | $80 | $85
Ibandronato | Boniva^®^ | 2.5 mg una vez al día | Pastilla | ND | $100
Ibandronato | Boniva^®^ | 150 mg una vez al mes | Pastilla | ND | $100
Ibandronato | Boniva^®^ | 3 mg una vez cada 3 meses | IV | ND | $485^4^
Risedronato | Actonel^®^ | 5 mg una vez al día | Pastilla | ND | $100
Risedronato | Actonel^®^ | 35 mg una vez a la semana | Pastilla | ND | $90
Risedronato | Actonel^®^ | 75 mg una vez al día, 2 días al mes | Pastilla | ND | $100
Risedronato | Actonel^®^ | 150 mg una vez al mes | Pastilla | ND | $100
Ácido zoledrónico | Reclast^®^ | 5 mg una vez al año | IV | ND | $105^5^
SERMS
Raloxifeno | Evista^®^ | 60 mg una vez al día | Pastilla | ND | $100
HORMONAS
Calcitonina | Miacalcin^®^, Fortical^®^ | 100 IU una vez cada otro día | Inyección | ND | $425
Calcitonina | Miacalcin^®^, Fortical^®^ | 200 IU una vez al día | Aerosol nasal | ND | $115
Estrógeno | Premarin^®^ | 0.3 mg una vez al día | Pastilla | ND | $35
Estrógeno | Premarin^®^ | 0.45 mg una vez al día | Pastilla | ND | $40
Estrógeno | Premarin^®^ | 0.625 mg una vez al día | Pastilla | ND | $35
Estrógeno más progestina | Prempro^®^ | 0.3 mg/1.5 mg una vez al día | Pastilla | ND | $40
Estrógeno más progestina | Prempro^®^ | 0.45 mg/1.5 mg una vez al día | Pastilla | ND | $50
Estrógeno más progestina | Prempro^®^ | 0.625 mg/2.5 mg una vez al día | Pastilla | ND | $40
Estrógeno más progestina | Prempro^®^ | 0.625 mg/5 mg una vez al día | Pastilla | ND | $40
Estrógeno más progestina
Estrógeno más progestina | Premphase^®^ | 0.625 mg/5 mg una vez al día | Pastilla | ND | $55
Teriparatida | Forteo^®^ | 20 mcg una vez al día | Inyección | ND | $845

1 Estos medicamentos se incluyeron en los estudios de investigación.

2 Dosis aprobadas por la Food and Drug administration (FDa) para la prevención o tratamiento de la osteoporosis.

3 El costo promedio al por mayor proviene de Drug topics Redbook, 2007. El costo no incluye los gastos de la administración intravenosa.

4 Costo ($1455) promedio en el transcurso de 3 meses.

5 Costo ($1250) promedio en el transcurso de 12 meses.

IV = intravenosa (inyección en una vena).

ND = no está disponible como genérico.

SERM (del inglés selective estrogen receptor modulators) = moduladores selectivos del receptor de estrógeno.

Dosis y costo de vitaminas y minerales

Nombre genérico^1^ | Nombre de la marca | Dosis^2^ y frecuencia de administración | Cómo se toma | Costo por mes^2^
Nombre genérico^1^ | Nombre de la marca | Dosis^2^ y frecuencia de administración | Cómo se toma | Genérico | Marca
Calcio^3^ | Varios nombres de marca | 500 mg al día | Pastilla | $3 | El costo varía
Calcio^3^ | Varios nombres de marca | 1,000 mg al dia | Pastilla | $5 | El costo varía
Calcio^3^ | Varios nombres de marca | 1,200 mg al día | Pastilla | $6 | El costo varía
Vitamina D^3^ | Varios nombres de marca | 400 IU al día | Pastilla | $1 | El costo varía
Vitamina D^3^ | Varios nombres de marca | 800 IU al día | Pastilla | $2 | El costo varía

1 Estos medicamentos se incluyeron en los estudios de investigación.

2 El costo promedio al por mayor proviene de Drug topics Redbook, 2007.

3 No está aprobado por la FDa para tratar osteoporosis. Dosis similares a las utilizadas en estudios de investigación.

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía y materiales sobre la comparación de tratamientos y medicamentos para otros trastornos de salud, visite esta página Web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm (http://effectivehealthcare.ahrq.gov/index.cfm/guides-for-patients-and-consumers/informacion-en-espanol/)

### Para obtener una copia gratuita, llame a

AHRQ Publications Clearinghouse, (800) 358–9295

Pida la publicación de AHRQ número: 08(09)-EHC008-B

Si desea más información sobre la osteoporosis, visite la página Web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/osteoporosis.html

Para obtener información sobre osteoporosis y edad avanzada, visite la página Web de NIH Senior: www.nihseniorhealth.gov/osteoporosis/whatisosteoporosis/01.html

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 591 informes de investigación. La revisión se titula Comparative Effectiveness of Treatments to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis – 2007 (Comparación de la efectividad de tratamientos para prevenir fracturas en hombres y mujeres con baja densidad de los huesos u osteoporosis – 2007), y fue escrita por el Southern California Evidence-based Practice Center at RAND (Centro de Práctica Basada en la Evidencia del Centro de Medicina del Sur de California en RAND).

## Related Content

Research Review

Clinician Guide

Consumer Guide