# Cuando se tiene una biopsia del seno

Guía para las mujeres y sus familias

## Hechos resumidos

- La mayoría de las mujeres a las que se le hace una biopsia del seno no tienen cáncer del seno. Aproximadamente 4 de cada 5 biopsias del seno tienen resultados negativos de cáncer.
- Para hacer una biopsia del seno es necesario extraer una cantidad pequeña de tejido. Mediante una biopsia, se sabe si un bulto o área sospechosa es cáncer.
- Existen dos tipos principales de biopsias del seno: biopsia quirúrgica y biopsia central con aguja.
- Los efectos secundarios son menos comunes cuando se usa la biopsia central con aguja que con la biopsia quirúrgica.

## ¿Qué cubre esta guía?

Esta guía le puede ayudar a hablar con su médico o enfermera sobre las biopsias del seno. Si tiene un bulto en el seno o un área sospechosa en su mamograma, mediante una biopsia del seno se sabrá si se trata de cáncer. Esta guía presenta los diferentes tipos de biopsias y le explicará qué implicará tener una biopsia del seno. Esta guía presenta investigaciones sobre qué tan bien funcionan los diferentes tipos de biopsias para detectar cáncer. Además, trata sobre los posibles efectos secundarios. Se basa en una revisión, financiada por el gobierno, de informes de investigación sobre la biopsia del seno.

## ¿Qué no cubre esta guía?

Esta guía no trata sobre el tipo de biopsia del seno llamado biopsia con aguja fina. No se incluyó en la revisión de la investigación y no se utiliza frecuentemente. Esta guía no trata sobre biopsias del seno para hombres, debido a que la investigación no incluyó hombres. Tampoco incluye tratamientos para el cáncer del seno.

## Cómo detectar cáncer del seno

### Detección

La detección del cáncer del seno aumenta la posibilidad de sobrevivir el cáncer del seno. Los exámenes de detección pueden encontrar cánceres antes de que tenga síntomas y cuando pueden tratarse más. Se realizan dos exámenes comunes para detectar cáncer del seno.

#### Mamograma

Un mamograma es una radiografía del seno por medio de rayos X. Este examen busca cambios sospechosos en el tejido del seno. Puede detectar cáncer, aun cuando sea demasiado pequeño para sentirse. El mamograma es el mejor examen para la detección del cáncer del seno.

#### Examen del seno realizado por su médico o enfermera

Por lo general, es parte del examen anual de la mujer. Sin embargo, si usted se da cuenta de algún bulto en el seno o algún otro cambio que le preocupe, no espere. Haga una cita con su médico o enfermera para que la revise.

### Exámenes de seguimiento

Cuando se encuentre un área sospechosa en el mamograma o un bulto, probablemente su médico le pedirá que se haga más exámenes. Su médico puede enviarla a que se realice otro mamograma o ultrasonido del seno. Con estos exámenes, su médico sabrá si usted necesita una biopsia. La mayoría de las mujeres a las que se les piden más exámenes no necesitan una biopsia.

### Biopsia

Si los resultados del examen aún son sospechosos, su médico le recomendará una biopsia.

## ¿Qué es la biopsia del seno?

La biopsia es el único examen con el que se puede saber si un área sospechosa es cáncer. Durante la biopsia del seno, el médico extrae una pequeña cantidad de tejido.

Existen dos tipos principales de biopsias del seno. Una es la biopsia quirúrgica. La otra es la biopsia central con aguja.

El tipo de biopsia del seno recomendada por el médico puede depender de la apariencia del área sospechosa, del tamaño y de dónde esté ubicada en el seno.

Después de la biopsia, el tejido se envía a un médico que lo examinará con un microscopio. Este médico, llamado patólogo, busca si hay cambios en el tejido. El informe patológico confirma si hay o no hay cáncer. Aproximadamente en una semana se obtiene el informe.

## Tipos de biopsia del seno

### Biopsia quirúrgica

En la biopsia quirúrgica, generalmente se usa anestesia local. La anestesia local significa que se adormecerá el seno. Se le colocará una línea intravenosa y puede que se le dé medicamento que la adormecerá.

El cirujano hará un corte de una o dos pulgadas en el seno y extraerá una parte o todo el tejido sospechoso. También puede que se extraiga un poco del tejido de alrededor.

El radiólogo es un médico que se especializa en imágenes médicas (como los rayos X y los mamogramas). Si el área sospechosa se puede observar mediante un mamograma o ultrasonido, pero no se puede sentir, el radiólogo por lo general introduce un alambre delgado para marcarle el área al cirujano antes de la biopsia.

### Biopsia central con aguja

En la biopsia central con aguja, se usa anestesia local. El médico introduce una aguja hueca en el seno y extrae una cantidad pequeña del tejido sospechoso. El médico puede colocar una marca diminuta dentro del seno. Así se indica el lugar donde se realizó la biopsia.

Generalmente los radiólogos o cirujanos realizan las biopsias centrales con aguja usando equipo especial de imaginología o para obtener imágenes.

En la biopsia central con aguja dirigida por ultrasonido, se utiliza el ultrasonido para guiar la aguja hacia el área sospechosa. El ultrasonido usa ondas sonoras para crear una imagen del interior del seno. Es parecido a lo que se usa para ver el bebé en una mujer embarazada. Se acostará boca arriba o de lado para este procedimiento. El médico sostendrá el dispositivo de ultrasonido sobre su seno para guiar la aguja.

En la biopsia estereotáctica central con aguja, se utiliza equipo de rayos X y una computadora para guiar la aguja. Por lo general, para este tipo de biopsia, usted se acuesta boca abajo en una mesa especial. La mesa tendrá una abertura para el seno. Se le comprimirá el seno como se hace para tomar un mamograma.

En la biopsia central con aguja y técnica de manos libres, no se utiliza equipo de rayos X o ultrasonido. Se utiliza con menos frecuencia y sólo para bultos que pueden palparse en la piel.

Es común sentir ansiedad cuando se va a hacer una biopsia. Pregunte a su médico o enfermera qué se puede esperar. Podría ser útil que hablara con su familia y amigos. Además, podría necesitar que alguien la acompañe a la cita.

## Investigación sobre la biopsia del seno

### Exactitud

Las biopsias quirúrgicas y biopsias centrales con aguja funcionan bien para detectar cáncer del seno. Sin embargo, las biopsias no son cien por ciento exactas. Sólo en pocos casos, una biopsia puede no detectar el cáncer del seno.

Las biopsias quirúrgicas y las biopsias dirigidas con ultrasonido o estereotácticas centrales con aguja tienen casi la misma exactitud. Las biopsias centrales con aguja y técnica de manos libres son menos exactas.

De cada 100 mujeres que tienen cáncer del seno:

- 98 a 99 de los casos de cáncer del seno, se detectarán con biopsias quirúrgicas.
- 97 a 99 de los casos de cáncer del seno, se detectarán con biopsias estereotácticas o biopsias dirigidas por ultrasonido.
- 86 de los casos de cáncer del seno, se detectarán con biopsias de técnica de manos libres.

#### Efectos secundarios

Después de una biopsia, puede tener sangrado, moretones e infección. Con las biopsias centrales con aguja hay un riesgo mucho menor de tener estos problemas que con las biopsias quirúrgicas.

Rara vez se presentan efectos secundarios con algún tipo de biopsia central con aguja.

- De cada 100 mujeres que han tenido una biopsia central con aguja, menos de 1 tiene problemas graves como moretones, sangrado o infección.

Los efectos secundarios se presentan con más frecuencia con biopsias quirúrgicas.

- De cada 100 mujeres que han tenido biopsias quirúrgicas, hasta 10 presentan moretones graves.
- De cada 100 mujeres que han tenido biopsias quirúrgicas, aproximadamente 5 tienen infección.

Algunos medicamentos, incluida la aspirina, aumentan el riesgo de sangrado y moretones. Su médico le preguntará acerca de los medicamentos que toma. Probablemente necesite dejar de tomar algunos medicamentos unos cuantos días antes de la biopsia.

#### Dolor

En ocasiones, las mujeres que se hacen una biopsia quirúrgica necesitan que se les recete medicamento para controlar el dolor después del procedimiento. Las mujeres que tienen una biopsia central con aguja rara vez necesitan que les receten medicamento para el dolor.

## Resultados de la biopsia

Después de la biopsia, el patólogo que examinó el tejido le enviará el informe patológico a su médico. El informe indicará si el área sospechosa es cáncer o no. Su médico revisará el informe con usted. La espera de esos resultados puede ser difícil. Los resultados se obtienen en aproximadamente una semana.

### Si no se detecta cáncer

Si no se detecta cáncer, al resultado de la biopsia se le llama benigno. “Benigno” significa que no es cáncer. Algunos resultados benignos necesitan seguimiento o tratamiento. Hable con su médico o enfermera sobre lo que recomiendan.

### Si se detecta cáncer

Si se detecta cáncer, el informe mencionará el tipo de cáncer. Le ayudará a que usted y su médico hablen de los siguientes pasos a seguir. Por lo general, se le enviará con un especialista en cáncer del seno. Probablemente necesite más exámenes con equipo de imágenes o una cirugía. Toda esta información le ayudará a usted y a su médico a considerar sus opciones de tratamiento.

Dese tiempo para pensar. La mayoría de las mujeres con cáncer del seno tienen tiempo para considerar sus opciones.

Asegúrese de preguntar a su médico si no entiende los resultados de su examen. Después de revisar los resultados con su médico, pida una copia del informe patológico para su archivo personal.

## Preguntas para su médico o enfermera

### Al decidir tener una biopsia

¿Qué tipo de biopsia recomienda?

¿Por qué recomienda este tipo de biopsia?

¿Hay otras opciones?

¿Cuáles son los posibles efectos secundarios de mi biopsia?

¿Cuánto tiempo durará?

### Cómo prepararse para una biopsia

¿Cuántos días antes de mi biopsia debo dejar de tomar aspirina?

¿Debo evitar otros medicamentos?

¿Puede alguien acompañarme en el consultorio?

¿Necesito que alguien me lleve de regreso a casa?

¿Quién me dará los resultados?

¿Cuándo obtendré los resultados?

### Si mi biopsia es benigna

¿Qué tipo de seguimiento necesito?

¿Cuándo debo tener mi próximo mamograma?

### Si mi biopsia detecta cáncer

¿Cuáles son los siguientes pasos a seguir?

¿Qué opciones de tratamiento tengo?

¿Me puede informar de grupos de apoyo para mujeres con cáncer del seno?

## ¿Dónde puede obtener más información?

Visite www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol.

Pulse en la guías para pacientes y consumidores si desea imprimir una copia y aprender sobre otras condiciones.

Si desea ejemplares impresos gratuitos de esta guía, llame al 800-358-9295. Pida a la AHRQ Publications Clearinghouse la Publicación AHRQ Número 10-EHC007-B.

Si desea más información sobre la biopsia del seno, visite la página web de MedlinePlus: www.nlm.nih.gov/medlineplus/spanish/ency/article/003920.htm.

Si desea más información sobre el cáncer del seno y apoyo, visite la página web de MedlinePlus: http://www.nlm.nih.gov/medlineplus/spanish/ency/article/000913.htm.

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva de una revisión detallada de 107 informes de investigación. La revisión se titula Comparative Effectiveness of Core-Needle and Open Surgical Biopsy for the Diagnosis of Breast Lesions (Comparación de la efectividad de la biopsia quirúrgica abierta y de la biopsia central con aguja para el diagnóstico de lesiones en el seno) (2009) y fue escrita por el ECRI Institute Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Instituto ECRI).

## Related Content

Research Review

Clinician Guide

Consumer Guide