# Tratamientos para los niños con trastorno del espectro autista

Revisión de las investigaciones para los padres y personas que ayudan al cuidado

## ¿Es apropiada esta guía para el niño al que cuido?

### Es apropiada si

El niño al que cuida tiene entre 0 y 12 años de edad y padece un trastorno del espectro autista (TEA).

### No es apropiada si

El niño al que cuida es mayor de 12 años o tiene un trastorno conductual, emocional, de desarrollo o de aprendizaje diferente.

### ¿Qué cubre esta guía?

Esta guía describe las investigaciones sobre los posibles beneficios y efectos secundarios negativos de las terapias para los niños que tienen entre 0 y 12 años y padecen de TEA. Se creó para ayudarle a hablar con su médico, administrador escolar, trabajador social o representante del seguro médico, acerca de los programas y terapias.

### ¿De dónde proviene la información de esta guía?

La información de esta guía proviene de la revisión de más de 200 estudios realizada por un centro de investigación independiente. Financió este informe la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia del gobierno federal. El informe fue revisado por pacientes, médicos y otros investigadores. Se puede leer el informe completo en www.effectivehealthcare.ahrq.gov/autism1.cfm (disponible sólo en inglés).

## Conozca la condición de su hijo

### ¿Qué es el trastorno del espectro autista (TEA)?

El TEA incluye una variedad de síntomas conductuales.

Las dos características principales del TEA son:

- Dificultad para la interacción social y la comunicación
- Comportamientos, intereses y actividades repetitivas

### ¿Qué tan frecuente es el TEA?

En Estados Unidos, alrededor de uno de cada 68 niños padecen de TEA. Es aproximadamente cuatro veces más frecuente en niños que en niñas. Puede afectar a niños de todas las razas y clases sociales, dondequiera que vivan. Los investigadores no saben exactamente qué causa el TEA.

### Cada caso de TEA es diferente en cada niño

El TEA es lo que se llama un “trastorno de amplio espectro”, porque los síntomas son diferentes en cada niño. Los síntomas pueden ser desde leves hasta graves y pueden cambiar conforme el niño crece. El TEA es muy diferente en cada niño. Eso hace difícil entender el TEA y encontrar las mejores terapias.

## Conozca sus opciones

### ¿Cómo puedo entender todos los diferentes tratamientos?

Los tratamientos para el TEA se pueden agrupar en diferentes categorías (vea la figura de abajo). Cada categoría se enfoca en un tipo de tratamiento.

quatros imagos - una familia, los lobros, las pastillas, y una cabeza

Puesto que los niños con TEA pueden tener diferentes síntomas, cada familia deberá escoger entre los distintos tratamientos, terapias y programas existentes, según las necesidades del niño. El plan de tratamiento para su hijo puede incluir algunos tratamientos de cada una de estas categorías.

### ¿Qué información aportan las investigaciones?

Se están haciendo muchas investigaciones sobre cómo tratar los síntomas del TEA en los niños o ayudarles a vencer las dificultades del TEA. Sin embargo, para decidir si algo ayuda o no (o si es mejor que alguna otra cosa), los investigadores necesitan evaluar los resultados de muchos estudios y no de uno solo. Es posible que un estudio indique que algo ayudó, mientras que otro indique que no fue así. La información de esta sección describirá cada tipo de tratamiento y lo que han hallado los investigadores al evaluar todos los estudios en conjunto.

#### Programas conductuales

imago do una familia Estos programas abordan las destrezas sociales, la atención, el sueño, el juego, la ansiedad, la interacción con los padres y conductas desafiantes. Algunos programas ayudan también con el desarrollo general de los niños.

Muchos de estos programas utilizan a terapeutas especialmente capacitados que trabajan con los padres y los niños hasta 25 horas cada semana. Los programas pueden durar desde 12 semanas hasta 3 años. Se realizan en casas, escuelas y clínicas.

La intervención conductual intensiva temprana, la terapia cognitivo-conductual y el entrenamiento en destrezas sociales son tipos de programas conductuales. Las intervenciones conductuales intensivas tempranas se enfocan en el desarrollo general de los niños. Los programas como el Modelo Lovaas y el Modelo Denver de Inicio Temprano (Early Start Denver Model) se enfocan principalmente en el trabajo con niños. Otros programas, como el Entrenamiento en Respuestas Centrales (Pivotal Response Training) y el de Hanen Más que palabras (Hanen More Than Words), se concentran en enseñar a los padres cómo ayudar a sus hijos.

Los programas que utilizan terapias cognitivo-conductuales ayudan a los niños a manejar su ansiedad. El gato valiente (Coping Cat) y Enfrenta tus miedos (Facing Your Fears) son ejemplos de este tipo de programas.

Los programas de destrezas sociales se enfocan en las destrezas sociales, la atención y el juego. Los programas Aprendizaje de destrezas (Skillstreaming) ayudan a los niños mayores con sus destrezas sociales. Los programas como Atención conjunta, participación y regulación en el juego (Joint Attention Symbolic Play Engagment and Regulation; JASPER, por su sigla en inglés) tienen por objeto ayudar a los niños pequeños con problemas como las dificultades para el juego cooperativo.

Los programas conductuales de su zona pueden basarse en estos u otros modelos. Sin embargo, pueden conocerse por otros nombres.

##### ¿Ayudan?

- Las intervenciones conductuales intensivas tempranas que se concentran en ayudar a los niños con su desarrollo general pueden mejorar el razonamiento y las destrezas de comunicación en el niño pequeño. Las investigaciones no aclaran del todo si mejoran las destrezas sociales, las destrezas para llevar la vida cotidiana o la intensidad de los síntomas del TEA.
- Parecen promisorios los programas que enseñan a los padres cómo ayudar a sus hijos, pero los investigadores aún no saben si funcionan.
- La terapia cognitivo-conductual reduce la ansiedad en algunos niños mayores con TEA que no tienen otros retrasos del desarrollo y tienen destrezas promedio de razonamiento y lenguaje.
- Los programas de destrezas sociales pueden ayudar durante periodos breves a los niños de edad escolar que no tienen otros retrasos del desarrollo o el lenguaje. Se requieren más investigaciones para saber si los niños recuerdan y usan estas destrezas después de concluir los programas.
- Los programas que abordan la forma en que juegan los niños pueden mejorar su interacción social, pero se necesita más investigación para saberlo con certeza.

##### ¿Cuáles son los costos?

Los costos de los programas conductuales varían según el Estado. Los terapeutas cobran diferentes honorarios. Es posible que el seguro no cubra algunos costos. Deberá consultar a su aseguradora respecto a la cobertura. Es posible que le ofrezcan otros tipos de asistencia. Pregunte a su médico.

##### ¿Qué otras cosas debo considerar?

Debido al tiempo que se necesita, tal vez deba usted cambiar el horario o la rutina familiar para poder participar en algunos programas.

#### Programas de enseñanza y aprendizaje

Imago de los lobros Estos programas se ofrecen en escuelas u otros centros de enseñanza. Se concentran en las destrezas de aprendizaje y razonamiento y en métodos para una “vida integral”. Los programas de las escuelas pueden tener nombres distintos, pero muchos de ellos se basan en el método denominado Tratamiento y educación de los niños autistas y con problemas de comunicación (Treatment and Education of Autistic and Related Communication-Handicapped Children; TEACCH, por su sigla en inglés). Los programas como TEACCH utilizan recursos visuales y acomodan el aula de forma que sea más fácil de manejar para un niño con TEA. Otros programas se aplican en el aula o el centro de enseñanza y utilizan estrategias de “análisis conductual aplicado” (conocido por su sigla en inglés ABA), como es el refuerzo positivo.

##### ¿Ayudan?

- Algunos niños del programa TEACCH mostraron mejoría en las destrezas motoras (la capacidad de caminar, correr, sostener objetos o sentarse derecho), la coordinación ojo-mano y el pensamiento y el razonamiento. Aun así, no hubo suficientes estudios para que los investigadores pudieran confirmar la eficacia de TEACCH.
- Otros programas educativos no se han estudiado lo suficiente para saber si funcionan.

##### ¿Cuáles son los costos?

Por lo general, estos servicios se incluyen en el costo de la escuela o el centro de enseñanza, para que no haya otros costos, si es residente del distrito escolar o de la comunidad.

##### ¿Qué otras cosas debo considerar?

Su distrito escolar o centro de aprendizaje puede dar otro nombre a estos métodos educativos, así que tal vez quiera preguntar qué tipos de estrategias utilizan exactamente. Es posible que las escuelas u otras instituciones públicas ayuden a pagar estos programas si tienen algún costo.

#### Medicamentos

##### Imago de los pastillas ¿Qué medicamentos se utilizan para tratar los síntomas del TEA?

- Antipsicóticos:
  - Risperidona (nombre comercial: Risperdal^®^).
  - Aripiprazol (nombre comercial: Abilify^®^).
- Inhibidores de la recaptación de serotonina, o SRI, por su sigla en inglés (antidepresivos).
  - Ejemplos: Prozac^®^, Sarafem^®^, Celexa^®^ y Cipramil^®^.
- Estimulantes y otros medicamentos para la hiperactividad.
  - Ejemplos: Ritalin^®^, Adderall^®^ y Tenex^®^.
- Secretina. Este medicamento se usa para tratar problemas digestivos, pero algunos investigadores pensaron que podría ayudar también a los niños con síntomas de TEA.
- Quelación. Este tratamiento utiliza sustancias para retirar del organismo metales pesados que algunos investigadores piensan que causan autismo.

##### ¿Ayudan?

- Las investigaciones indican que dos medicamentos antipsicóticos –risperidona (Risperdal^®^) y aripiprazol (Abilify^®^)– pueden ayudar a reducir el sufrimiento emocional, la agresividad, la hiperactividad y la tendencia a autolesionarse. Muchas personas que toman risperidona y aripiprazol informan efectos secundarios tales como aumento de peso, sueño excesivo, temblores y movimientos anormales. Debido a esos efectos secundarios, estos medicamentos pueden ser más adecuados solamente para los niños que tienen síntomas más graves o cuyos síntomas pueden aumentar el riesgo de que se haga daño a sí mismo.
- Los SRI y un medicamento para la hiperactividad llamado metilfenidato (Ritalin^®^) no se han estudiado lo suficiente para saber si ayudan a tratar los síntomas del TEA.
- Las investigaciones mostraron que la secretina no es eficaz para mejorar los síntomas de autismo.
- Según la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos, los productos para la quelación conllevan problemas de seguridad graves. Aun cuando se usen bajo vigilancia médica, estos productos pueden causar daños graves, entre ellos deshidratación, insuficiencia renal y muerte. Las investigaciones no respaldan el uso de la quelación para tratar el TEA.

##### ¿Cuáles son los costos?

El costo para usted de cada tipo de medicamento dependerá de su seguro médico, de la cantidad (dosis) que su hijo deba tomar y de si el medicamento existe también en forma genérica.

#### Otros tratamientos y terapias

imago de una cabeza. Es posible que haya usted oído o leído de otros tipos de tratamientos o terapias que se han utilizado en niños con TEA; por ejemplo:

- Terapias del habla y el lenguaje.
- Terapia con música.
- Terapia ocupacional.
- Acupuntura.
- Suplementos de vitaminas y minerales.
- Terapia con masajes.
- El Sistema de comunicación con intercambio de imágenes.
- Enseñanza en un medio prelingüístico y educación de respuesta.
- Neurorretroalimentación.
- Educación y entrenamiento del sueño.

##### ¿Ayudan?

Estas otras terapias no se han estudiado lo suficiente para saber si ayudan o tienen algún efecto secundario. Eso no significa que no sean eficaces o seguros. Significa simplemente que los investigadores no tienen suficiente información para confirmarlo.

##### ¿Qué otras cosas debo considerar?

Puesto que se sabe poco sobre la eficacia de estos tratamientos o terapias, la decisión de probarlos se facilitará si habla al respecto con su médico, otros profesionales de salud o de la educación, su familia y otras personas de su confianza.

### ¿Por qué se sabe tan poco sobre el TEA y estos tratamientos?

Las investigaciones revisadas para esta guía demuestran que algunos tratamientos pueden producir mejorías específicas en la forma en que el niño piensa o actúa. Pero los investigadores no poseen información suficiente para saber si algún tipo de tratamiento permite obtener mejores resultados que otro. Respecto a la mayoría de los tratamientos, los investigadores tampoco saben cuál o cuáles actúan mejor en cada caso específico. Por ejemplo, las investigaciones no indican si un programa suele ser mejor en niños de edad mayor o menor, o en niños con TEA grave o menos grave.

Eso no significa que un tratamiento, terapia o programa no serán útiles para su hijo. Significa simplemente que los investigadores no tienen información suficiente para poder afirmarlo con plena certeza.

Los investigadores todavía están estudiando estos tratamientos y terapias. Consulte a su médico o grupo de apoyo para enterarse de nuevas investigaciones acerca de los programas y tratamientos que se describen en esta guía y de nuevas opciones.

## Tome una decisión

Al escoger terapias o programas para su hijo, debe considerar muchos factores. Deberá hablar con muchas personas, en particular con su médico, el trabajador social, el administrador escolar y el representante de su seguro médico. He aquí algunas preguntas que querrá hacer:

### ¿Cuál es el mejor plan para mi hijo?

- ¿Cree usted que le ayudaría una intervención intensiva temprana?
- ¿Qué otros tipos de programas podrían ser útiles?
- ¿Cree usted que le convenga tomar medicamentos?

### ¿Qué recursos puedo encontrar en mi comunidad?

- ¿Existen programas de intervención intensiva temprana en esta comunidad?
- ¿Las escuelas de este distrito escolar tienen programas para niños con TEA?
- ¿Qué grupos de apoyo existen?

### ¿Cuáles son los costos?

- ¿Cuánto nos costará a nosotros participar en esos programas?
- ¿Ofrecen apoyo las escuelas u otras instituciones públicas?
- ¿Cubre algún costo mi seguro médico?

### ¿Qué cambios tendremos que hacer en nuestros horarios de trabajo y en la vida cotidiana?

- ¿Cuánto tiempo requiere cada opción?
- ¿En qué forma otras familias han adaptado a su vida estos programas?
- ¿Qué más podemos hacer para ayudar a nuestro hijo?

### ¿Qué medicamento, si lo hay, es el mejor para mi hijo?

- ¿Qué síntomas aliviarán los medicamentos?
- ¿En cuánto tiempo podré ver cambios en los síntomas de mi hijo?
- ¿Cuáles serían los signos de advertencia de que mi hijo tiene un efecto secundario dañino?
- ¿Qué otras opciones hay si mi hijo necesita cambiar de medicamento?

## Fuente

La información de esta guía proviene de los informes Comparative Effectiveness of Therapies for Children With Autism Spectrum Disorders (Comparación de la eficacia de los tratamientos para niños con trastornos del espectro autista) y Therapies for Children With Autism Spectrum Disorder: Behavioral Interventions Update (Terapias para niños con trastorno del espectro autista: actualización en intervenciones conductuales). Los informes fueron producidos por el Vanderbilt Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Vanderbilt) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés). Para obtener una copia de los informes o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/autism1.cfm (disponible sólo en inglés).

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas) en el Baylor College of Medicine (Facultad de Medicina de Baylor), en Houston, Texas. Fue revisado por padres y personas que ayudan al cuidado de niños con TEA. Investigadores de la AHRQ lo actualizaron en 2014.

Esta guía fue traducida de la publicación en inglés titulada Therapies for Children With Autism Spectrum Disorder: A Review of the Research for Parents and Caregivers.