# Tratamiento para la apnea del sueño

Revisión de la investigación para adultos

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Un médico le dijo que tiene “apnea obstructiva del sueño” (OSA por su sigla en inglés) de grado leve, moderata o grave. Las personas con OSA pueden roncar y detener (“pausar”) su respiración algunas o muchas veces mientras duermen.
- Está buscando maneras de tratar su apnea del sueño y quiere saber lo que dicen las investigaciones sobre sus opciones.
- Es una persona adulta. La guía no cubre el tratamiento para niños:

### No es apropiada si

- Su médico le dijo que usted tiene “apnea central del sueño”, la cual es una condición diferente y necesita otros tipos de tratamiento.
- Ronca muy fuerte, pero el médico le ha dicho que no tiene OSA. No toda la gente que ronca tiene OSA.

Hay varias formas que le ayudan a los médicos a saber si tiene OSA. Si piensa que tiene esta condición, hable con su médico.

### ¿De dónde proviene la información?

Un equipo independiente de investigadores, financiado por la Agency for Healthcare and Research Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés) revisó la investigación actual acerca de los tratamientos para la apnea del sueño. Este informe fue revisado por clínicos, investigadores, expertos y público en general. El informe puede leerse en www.effectivehealthcare.ahrq.gov/apnea.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es apnea del sueño?

La apnea obstructiva del sueño, conocida también en inglés como OSA, es un trastorno crónico (continuo). Las personas que padecen de OSA, detienen o “pausan” su respiración o no respiran profundamente cuando duermen.

Casi todos tenemos momentos breves en los que dejamos de respirar mientras dormimos. Las personas con OSA:

- Detienen la respiración o el flujo de aire (lo cual se llama “hipoapnea”) con mayor frecuencia de lo normal.
- Pueden empezar a respirar otra vez con un ronquido fuerte o un sonido de ahogo.
- Tienen cinco o más pausas respiratorias cada hora; a veces hasta una o dos veces cada minuto.

La OSA puede ser leve, moderada o grave, dependiendo de:

- Cuántas pausas respiratorias o disminuciones del flujo de aire ocurran cada hora.
- Qué tan bajo sea el nivel de oxígeno en la sangre de la persona durante esos periodos.
- La cantidad de sueño que la persona sienta durante el día.

### ¿Qué tan común es la OSA?

- La apnea del sueño es muy común y afecta a personas de todas las edades.
- Las personas de mediana y edad avanzada, así como las personas obesas (con mucho sobrepeso) son más propensas a padecer de esta condición.
- 12 millones de personas tienen OSA en Estados Unidos, según datos de los National Institutes of Health (Institutos Nacionales de la Salud). Muchas más personas pueden tener apnea del sueño y no lo saben debido a que no se han hecho las pruebas necesarias.

### ¿Qué tan grave es la OSA?

Si no se trata, la OSA puede:

- Causar que la persona no duerma bien, y por lo tanto, tenga mucho sueño en el día.
- Aumentar el riesgo de accidentes de automóvil o relacionados con el trabajo, debido a que tienen sueño.
- Aumentar el riesgo de problemas de salud graves, como la diabetes, e incluso la muerte.

### ¿Cómo sabe mi médico si tengo OSA?

- Su médico puede hacerle preguntas para averiguar si tiene síntomas de OSA.
- Su médico o personal de atención médica puede pedirle que se haga un “estudio del sueño”. Este consiste en pasar una noche en una clínica especial, donde profesionales capacitados observan su respiración, frecuencia cardiaca (latidos por minuto) y otros signos vitales mientras usted duerme.
- Su médico puede seleccionar un monitor para que lo use en casa con el fin de saber con qué frecuencia usted pausa, deja de respirar o tiene menos flujo de aire cuando duerme.
  ▲ Algunas investigaciones señalan que el monitor de casa puede indicarle al médico si una persona tiene OSA, aunque no con la misma precisión que los estudios del sueño que se hacen en una clínica especial y de noche mientras duerme.
  ▲ Si usted tiene apnea del sueño moderada o grave, su médico puede enviarlo a que vea a un especialista en medicina del sueño. Esta persona puede ser un “pulmonólogo”, un internista o un médico del oído, nariz y garganta (otorrinolaringólogo).

## Conozca sus opciones

### ¿Qué opciones de tratamiento tengo?

#### Máquina de presión positiva continua en las vías respiratorias (CPAP, por su sigla en inglés)

- Una máquina de CPAP impulsa una corriente de aire mediante una mascarilla que la persona usa cuando duerme. El aire entra por la mascarilla a la nariz o la boca para mantener abiertas la garganta y la vía respiratoria.
- Hay muchos tipos de máquinas CPAP y mascarillas. Algunas mascarillas se amoldan a la nariz y otras le cubren la nariz y la boca.
- La CPAP es el tratamiento para la OSA que más se utiliza y más se ha investigado. Por lo general, es el primer tratamiento que el médico recomienda para la OSA.

#### Dispositivo para el avance mandibular (MAD, por su sigla en inglés)

- El MAD es un aparato bucal que la persona usa para dormir.
- Hay muchos tipos de MAD. La mayoría están hechos de plástico duro y cubren los dientes de arriba y de abajo. Algunos también mantienen la lengua en su lugar.
- El aparato bucal mantiene la mandíbula hacia adelante y la vía respiratoria abierta.
- Estos aparatos los venden y colocan los dentistas o los ortodoncistas, después de hacerle un molde a su boca.

Imagen reproducida con autorización de la Mayo Foundation for Medical Education and Research (Fundación Mayo para la Educación y la Investigación Médica)

Todos los derechos reservados.

Posiblemente vea usted anuncios de aparatos bucales que se pueden comprar directamente y que no necesitan ser ajustados por un médico. Esos anuncios pueden asegurar que ayudan a quitar los ronquidos o incluso la apnea. Pero, esos productos no son iguales a los MAD que han estudiado los investigadores. Siempre pregunte a su médico o dentista antes de comprar un aparato bucal.

### ¿Qué diferencias o semejanzas existen entre estas dos opciones?

Algunos estudios han encontrado que:

- Tanto CPAP como MAD reducen el sueño durante el día y disminuyen el número de veces que usted pausa o deja de respirar cuando duerme.
- La CPAP funciona mejor que el MAD, ya que reduce el número de pausas respiratorias a menos de cinco por hora, que es lo normal.
- La CPAP y el MAD causan algunos efectos secundarios:
  ▲ CPAP: Los más comunes son: sentirse “atrapado”, sequedad de nariz y boca, sangrado por la nariz, lesiones en los labios o encías, molestia en el pecho e irritación de la piel o la nariz.
  ▲ MAD: Dientes flojos o dañados y dolor en la mandíbula. Muchas personas que utilizan un MAD tienen que hacer ejercicios para “estirar” la mandíbula por la mañana o visitar al dentista regularmente para detectar posibles problemas dentales.

### ¿Cuanto tiempo necesitaré usar alguno de estos tratamientos?

- Para que sean eficaces, los dos tratamientos deben usarse siempre que se va a dormir.
- La mayoría de las personas deberán usar el CPAP o el MAD para toda la vida.

#### ¿Bajar de peso puede mejorar mi OSA?

- En algunas personas obesas (con mucho sobrepeso) la OSA se ha reducido o se ha curado al bajar de peso.
- Algunos estudios encontraron que los programas para bajar de peso son un tratamiento eficaz para la OSA en las personas con sobrepeso.

#### ¿Hay otras opciones de tratamiento?

##### Cirugía

- Algunas personas con OSA pueden hacerse una o más cirugías para retirar el tejido de la parte posterior de la garganta. De esa manera se ensancha la vía respiratoria.
- Algunas personas que padecen de OSA grave y que tienen sobrepeso se hacen una cirugía para limitar la cantidad de alimento que llega al estómago. Ésta se conoce como cirugía “bariátrica” y ayuda a las personas a bajar de peso.
- Cualquier tipo de cirugía conlleva riesgos, tales como: hemorragia, infección, daño a los nervios e incluso la muerte.
- Después de la cirugía puede tener dificultad para tragar, cambios en la voz o el habla o reducción en el grosor de la vía respiratoria.

No existe suficiente investigación para comparar la cirugía con los otros tratamientos para la apnea del sueño. Los investigadores consideran que la cirugía puede mejorar la apnea del sueño, pero no saben qué tanto, ni a quiénes pueda ofrecer el mayor beneficio.

Tal vez oiga usted de muchos otros tratamientos y productos que aseguran poder eliminar el ronquido o la apnea del sueño. Pero, no existe suficiente investigación que confirme si funcionan, ni qué tan bien lo hagan.

A diferencia de otras condiciones médicas, distintos tipos de médicos, entre ellos los dentistas, ofrecen tratamientos para la OSA. Cada tipo de médico puede ofrecer una opción diferente. Pídale a cada médico que le explique todas sus opciones.

## Tome una decisión

### Cosas que debo considerar

Hay varias cosas que debe considerar antes de decidir cómo tratar su OSA:

- Los riesgos y beneficios de cada opción de tratamiento.
- El costo de cada opción de tratamiento.
- Qué tratamiento se ajusta mejor a sus preferencias, lo que no le gusta y los valores importantes para usted.
- Qué tratamiento es más probable que use realmente cada noche.

### ¿Cuáles son los costos del tratamiento?

El costo para usted de cada opción de tratamiento depende del tipo de seguro médico que tenga.

#### CPAP

- Las máquinas y suministros para la CPAP se consideran “equipo médico duradero”, que su seguro puede cubrir de una manera distinta a los medicamentos u otros servicios médicos. Pregunte al administrador de su plan de salud cuánto pagará su seguro médico por el equipo de CPAP.
- Algunos planes de seguro exigirán que use un tipo o marca específica de máquina y mascarilla de CPAP. Otros planes le permitirán escoger entre varias marcas.
- Algunas máquinas de CPAP vienen con humidificador, lo que aumenta su costo. Algunas personas sienten que los humidificadores reducen los efectos secundarios y hacen más confortable la CPAP.
- El costo para el público (antes del pago del seguro) de la mayoría de las máquinas de CPAP está entre $300 y $2,000.
- El costo promedio de los suministros de CPAP (mascarilla, tubos y filtros) está entre $300 y $800 por año.

#### MAD

- Su plan de salud puede también cubrir el MAD como “equipo médico duradero”.
- Algunos planes de salud pueden no cubrir estos aparatos, mientras que otros los pueden cubrir bajo su plan dental. Consúltelo con el administrador de su seguro médico.
- Algunos MAD necesitan ajustarse o reemplazarse. Esto puede aumentar el costo.
- El uso de un MAD puede requerir que acuda usted al dentista con mayor frecuencia, para detectar problemas dentales o de la mandíbula.
- El costo para el público (antes del pago del seguro) de un MAD está entre $300 y $2,500.
- En Internet se anuncian aparatos bucales de menor costo para tratar los ronquidos y la apnea del sueño, pero puede que éstos no le ayuden a mejorar la apnea del sueño. Hable con su médico antes de usar estos dispositivos o aparatos bucales.

#### Programas para bajar de peso

- El costo de estos programas varía entre unos cientos de dólares y varios miles de dólares al mes.
- Es posible que su plan de salud no cubra el costo de estos programas, pero su empleador puede ofrecer descuentos, como parte de su plan de beneficios (prestaciones).

#### ¿Cómo se adaptarán estos tratamientos a mi estilo de vida?

- La CPAP necesita probarse en un estudio de sueño nocturno, para asegurarse que funciona. El MAD pueden necesitar que un dentista lo ajuste varias veces.
- Acostumbrarse al CPAP o al MAD puede llevar tiempo. Pueden ser incómodos al principio.
- Los programas para bajar de peso pueden requerir que cambie sus hábitos alimenticios y tomará tiempo ver los resultados.
- Las personas con apnea deben evitar las bebidas alcohólicas y los medicamentos narcóticos.

### Pregunte a su médico

- ¿Qué piensa de las investigaciones sobre los tratamientos de la OSA?
- ¿Qué opción de tratamiento cree que sea mejor para mí?
- ¿Hay manera de hacer que estos tratamientos sean más cómodos?
- ¿Qué debo hacer si no puedo usar el tratamiento todos los días?
- ¿Hay opciones menos-costosas que pueda usar primero? ¿Por qué sí o por qué no?

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información en este resumen proviene del informe Diagnosis and Treatment of Obstructive Sleep Apnea in Adults (‘Diagnóstico y tratamiento de la apnea obstructiva del sueño en adultos’). El informe fue producido por el Tufts Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Tufts), con el financiamiento de la Agency for Healthcare Research and Quality (AHRQ por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite http://www.effectivehealthcare.ahrq.gov/apnea.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web de Medline-Plus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Este servicio está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor), de Houston, TX. Revisaron esta guía, adultos con apnea del sueño.