# Medicamentos antipsicóticos para niños y adolescentes

Revisión de la investigación para padres y personas que ayudan al cuidado

## ¿Es esta información apropiada para el niño que cuido?

### Es apropiada si

- Un médico ha dicho que su niño (de 1 a 18 años de edad) tiene una de estas condiciones:
  - Esquizofrenia y psicosis causada por ezquizofrenia
  - Trastorno bipolar
  - Trastornos del desarrollo, como autismo, síndrome de Asperger y otros trastornos del espectro autista
  - Síndrome de Tourette
  - Trastorno de déficit de atención e hiperactividad (ADHD, por su sigla en inglés)
  - Trastornos de comportamiento perturbador, incluidos el trastorno de oposición desafiante y el trastorno de la conducta
- Un médico ha sugerido incluir en el tratamiento uno de los medicamentos antipsicóticos siguientes:
  - Aripiprazol (Abilify^®^)
  - Clozapina (Clozaril^®^, FazaClo^®^)
  - Olanzapina (Zyprexa^®^)
  - Paliperidona (Invega^®^)
  - Quetiapina (Seroquel^®^)
  - Risperidona (Risperdal^®^)
  - Ziprasidona (Geodon^®^)

Nota: Los medicamentos antipsicóticos pueden causar efectos secundarios serios. Dependiendo de la condición del niño, el médico puede sugerir primero un tipo diferente de medicamento antes de sugerir un antipsicótico. El médico también puede sugerir tratamientos sin medicamentos.

### No es apropiada si

- Un médico no ha dicho que el niño tenga una de estas condiciones y no ha sugerido incluir un medicamento antipsicótico en el tratamiento de su niño.

### ¿Qué aprenderé con este resumen?

Este resumen habla del uso de medicamentos antipsicóticos para tratar trastornos psiquiátricos en los niños. Explica lo que dice la investigación médica acerca de los beneficios y posibles efectos secundarios que pueden ocurrir en los niños que toman estos medicamentos. Este resumen no aborda otros medicamentos para tratar los trastornos psiquiátricos ni las opciones de tratamiento sin medicamentos. Puede ayudarle a hablar con el médico de su niño para decidir si es apropiado que use un medicamento antipsicótico.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 81 estudios publicados entre enero de 1987 y febrero de 2011 acerca del uso de medicamentos antipsicóticos en niños y escribieron un informe de los resultados. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/pedantipsych.cfm (disponible sólo en inglés).

## Conozca los antipsicóticos

### ¿Qué son los medicamentos antipsicóticos?

Los medicamentos antipsicóticos fueron creados para ayudar a las personas que padecen psicosis, pero ahora se utilizan también para tratar muchas condiciones distintas en niños y adultos. Funcionan modificando la forma en que ciertas sustancias químicas actúan en el cerebro. El hecho de que el niño use estos medicamentos no significa que tenga psicosis.

Los medicamentos antipsicóticos se dividen en dos “generaciones”. Los médicos suelen referirse a ellos como antipsicóticos “antiguos” (también llamados “típicos”) o como antipsicóticos “nuevos” (también llamados “atípicos”).

Antipsicóticos

Nombre del medicamento | Nombre comercial
Antipsicóticos antiguos
Clorpromazina | Thorazine^®^
Haloperidol | Haldol^®^
Pimozida | Orap^®^
Antipsicóticos nuevos
Aripiprazol | Abilify^®^
Asenapina^*^ | Saphris^®^*
Clozapina | Clozaril^®^; FazaClo^®^
Iloperidona^*^ | Fanapt^®^*
Lurasidona^*^ | Latuda^®^*
Olanzapina | Zyprexa^®^
Paliperidona | Invega^®^
Quetiapina | Seroquel^®^
Risperidona | Risperdal^®^
Ziprasidona | Geodon^®^

* Estos medicamentos no se estudiaron en este informe.

A veces, los médicos prescriben estos medicamentos para muchas condiciones distintas a la psicosis. Los antipsicóticos no pueden curar estas condiciones. Se utilizan para aliviar los síntomas y mejorar la calidad de vida. Entre estas condiciones están:

- Trastornos generalizados del desarrollo (incluidos autismo, síndrome de Asperger y otros trastornos del espectro autista)^*^
- Síndrome de Tourette
- Trastorno de déficit de atención e hiperactividad (ADHD, por su sigla en inglés)
- Trastornos de comportamiento perturbador (incluidos el trastorno de oposición desafiante y el trastorno de la conducta)

Dependiendo de la condición del niño, el médico puede sugerir primero un tipo diferente de medicamento antes de sugerir un antipsicótico. El médico puede también sugerir tratamientos sin medicamentos, como la terapia de conversación o psicoterapia.

### ¿Qué dicen las investigaciones sobre la eficacia de los medicamentos antipsicóticos?

En general, los antipsicóticos nuevos buscan aliviar los síntomas de algunas condiciones psiquiátricas en los niños.

Los investigadores observaron que:

- Los antipsicóticos mejoran los síntomas de la esquizofrenia.
- La olanzapina (Zyprexa^®^), la risperidona (Risperdol^®^) y la clozapina (Clozaril^®^ o FazaClo^®^) parecen actuar casi igual para aliviar los síntomas de la esquizofrenia. No existe suficiente investigación para saber qué tan bien funcionan los otros antipsicóticos cuando se comparan entre sí.
- Los antipsicóticos nuevos parecen actuar mejor que los antipsicóticos antiguos para tratar los síntomas de la esquizofrenia, pero no existe suficiente investigación para saberlo con certeza.
- Después de cierto tiempo, los antipsicóticos nuevos mejoran los síntomas del trastorno bipolar.
- En los niños con trastorno bipolar, los antipsicóticos nuevos no reducen los pensamientos suicidas ni la tasa de suicidio.
- La olanzapina (Zyprexa^®^) y la risperidona (Risperdol^®^) parecen actuar mejor que el antipsicótico antiguo haloperidol (Haldol^®^) para reducir la irritabilidad y la agresividad en los niños con autismo, pero no existe suficiente investigación para saberlo con certeza.
- La risperidona (Risperdol^®^) y la ziprasidona (Geodon^®^) tienen la función de reducir los tics en los niños con síndrome de Tourette.
- La risperidona (Risperdol^®^) tiene la función de aliviar los síntomas de ADHD y los trastornos de comportamiento perturbador.

Los estudios de investigación se realizaron en niños diagnosticados con una sola condición. Las investigaciones no pueden indicarnos qué tan bien funcionan los antipsicóticos en los niños diagnosticados con más de una condición.

### ¿Cuáles son los posibles efectos secundarios de los medicamentos antipsicóticos?

La Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA, por su sigla en inglés) de Estados Unidos lista los siguientes posibles efectos secundarios que pueden causar los medicamentos antipsicóticos.

Los antipsicóticos nuevos pueden causar:

- Aumento de peso. Es importante vigilar el peso de su niño mientras está tomando un medicamento antipsicótico.
- Un mayor riesgo de tener niveles altos de colesterol o triglicéridos (un tipo de grasa) en la sangre.
- Un mayor riesgo de tener niveles altos de azúcar en la sangre y diabetes.
- Presión arterial baja.

El aripiprazol (Abilify^®^) y la quetiapina (Seroquel^®^) pueden aumentar el riesgo de que los niños tengan pensamientos suicidas.

Los antipsicóticos antiguos y nuevos pueden causar:

- Sueño excesivo.
- Movimientos incontrolables, como tics y temblores.
- Mareos, dolores de cabeza y boca seca.
- Aumento en el cuerpo del nivel de una hormona llamada prolactina. Un aumento de la prolactina puede retrasar la madurez sexual tanto en los niños como en las niñas. Puede causar períodos menstruales anormales o interrumpir esos períodos en las adolescentes. Puede también causar desarrollo anormal de los senos en los jóvenes de ambos sexos.
- Una reacción que puede llegar a causar la muerte, llamada “síndrome neuroléptico maligno”, aunque es rara. Los síntomas incluyen fiebre alta, sudor excesivo, grandes variaciones de la presión arterial y rigidez de los músculos.

La FDA advierte que, en algunas personas, la clozapina (Clozaril^®^ o FazaClo^®^) puede causar una condición grave en la sangre que disminuye drásticamente el total de glóbulos blancos en ciertas personas. El médico de su niño necesitará realizar análisis de sangre frecuentes para vigilar el total de glóbulos blancos mientras su niño toma este medicamento. La clozapina puede también causar convulsiones o inflamación del corazón.

### ¿Qué dicen las investigaciones sobre los efectos secundarios de los medicamentos antipsicóticos y cómo se comparan?

Algunos estudios encontraron los resultados siguientes, pero no existe suficiente investigación para saberlo con certeza:

- Más niños parecieron subir de peso cuando tomaron olanzapina (Zyprexa^®^) que los que tomaron aripiprazol (Abilify^®^) o risperidona (Risperdal^®^).
- Más niños parecieron tener aumento del colesterol y los triglicéridos cuando tomaron olanzapina (Zyprexa^®^) que los que tomaron aripiprazol (Abilify^®^), quetiapina (Seroquel^®^) o risperidona (Risperdal^®^).
- Menos niños parecieron tener aumento de peso y aumento del colesterol cuando tomaron aripiprazol (Abilify^®^) que los que tomaron quetiapina (Seroquel^®^).
- Más niños parecieron tener aumento de la hormona prolactina cuando tomaron risperidona (Risperdal^®^) que los que tomaron olanzapina (Zyprexa^®^).
- Menos niños parecieron subir de peso cuando tomaron el antiguo antipsicótico haloperidol (Haldol^®^) que los que tomaron antipsicóticos nuevos.
- Los niños que tomaron el antipsicótico antiguo haloperidol (Haldol^®^) parecieron tener mayor riesgo de desarrollar movimientos incontrolables, tales como tics y temblores, que los que tomaron antipsicóticos nuevos.
- Los medicamentos antipsicóticos pueden tener a largo plazo otros efectos secundarios que no se detectaron en los estudios de investigación, como el desarrollo de niveles altos de azúcar en la sangre y diabetes.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Deberán considerarse varias cosas al decidir si un medicamento antipsicótico es apropiado para su niño. Solamente usted y el médico de su niño pueden decidir si la posible capacidad que tenga cualquier medicamento de ayudar compensa, el riesgo de padecer un efecto secundario grave. Cada niño responde en forma distinta a los diferentes medicamentos antipsicóticos. El médico puede probar con varios medicamentos antes de encontrar el correcto. También es importante hablar con el médico de su niño acerca de otras opciones para tratar su condición, tales como otros medicamentos y tratamientos sin medicamentos.

Usted y el médico de su niño deben hablar sobre:

- Qué tan bien podrían funcionar otros medicamentos distintos a los antipsicóticos, para aliviar los síntomas de su niño.
- Qué opciones de tratamiento sin medicamentos existen y si podrían ayudar a su niño.
- Los beneficios de tomar un antipsicótico o de agregar uno al tratamiento.
- Qué medicamento antipsicótico funcionaría mejor para su niño, de acuerdo con su edad y condición.
- Los efectos secundarios posibles de tomar un antipsicótico, especialmente el aumento de peso, sueño excesivo y movimientos incontrolables, como tics y temblores.
- El riesgo de tener un efecto secundario grave.
- Maneras de ayudarle a identificar los efectos secundarios, para que puedan tratarse o para cambiar el medicamento.
- Qué opción de tratamiento se ajusta mejor a lo que le agrada, lo que le desagrada y a sus valores.
- El costo de cada medicamento.

### ¿Cuánto cuestan los medicamentos?

El costo para usted de estos medicamentos depende de:

- Su seguro médico.
- La dosis (cantidad) de medicamento que su niño deba tomar.
- Si el medicamento existe en la forma genérica.

Costos de mayoreo de los antipsicóticos con receta

Nombre comercial | Dosis | Costo por mes del comercial^*^ | Nombre del medicamento | Costo por mes del genérico^*^
Antipsicóticos antiguos
Thorazine^®^ | 10–75 mg | ND | Clorpromazina | $25–$45
Haldol^®^ | 1–10 mg | ND | Haloperidol | $10–$45
Orap^®^ | 0.5–10 mg | $45–$310 | Pimozida | ND
Antipsicóticos nuevos
Abilify^®^ | 2–30 mg | $660–$930 | Aripiprazol | ND
Clozaril^®^; FazaClo^®^ | 75–500 mg | $240–$1,225 | Clozapina | $115–$500
Zyprexa^®^ | 2.5–20 mg | $375–$1,330 | Olanzapina | $335–$1,215
Invega^®^ | 3–12 mg | $570–$1,145 | Paliperidona | ND
Seroquel^®^ | 25–800 mg | $110–$1,155 | Quetiapina | $100–$1,020
Risperdal^®^ | 0.25–6 mg | $165–$760 | Risperidona | $120–$535
Geodon^®^ | 40–160 mg | $550–$665 | Ziprasidona | ND

* Los precios son los precios de mayoreo promedio según el RED BOOK Online^®^ redondeados al valor de $5 más cercano.

Los precios del medicamento genérico son el promedio dentro del rango de precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los de esta lista, dependiendo de su seguro médico y del fabricante al que compre su farmacia.

ND = no disponible

### Pregunte al médico de su niño

- ¿Qué medicamento está considerando recetarle a mi niño? ¿Por qué?
- ¿Cuánto tiempo tardará en surtir efecto el medicamento?
- ¿Qué síntomas puede aliviar el medicamento y cómo podemos monitorear el progreso?
- ¿A qué efectos secundarios graves debo prestar atención y cuándo debo ponerme en contacto con el médico?
- ¿Cuánto peso puede aumentar mi niño por tomar un antipsicótico? ¿Cuándo debo contactarlo sobre el aumento de peso de mi niño?
- ¿Mi niño correrá el riesgo de tener colesterol alto, azúcar alta en la sangre o diabetes, si toma un antipsicótico?
- ¿Cuánto tiempo deberá mi niño tomar el medicamento?
- ¿Qué debemos hacer si el medicamento deja de funcionar?
- ¿Existen otras opciones de tratamiento además de los medicamentos? En ese caso, ¿cuáles son?

Otras preguntas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

Anote aquí las respuestas:

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

_____________________________________________________

## Fuente

La información de este resumen proviene del informe First- and Second-Generation Antipsychotics for Children and Young Adults (Antipsicóticos de primera y segunda generaciones para niños y adultos jóvenes), de febrero de 2012.

El informe fue producido por el University of Alberta Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Alberta), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/pedantipsych.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página web está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas que tienen a su cuidado a niños que han tomado antipsicóticos.

Esta guía fue traducida de la publicación en inglés titulada Antipsychotic Medicines for Children and Teens: A Review of the Research for Parents and Caregivers.

* Los antipsicóticos se utilizan para ayudar a los niños con autismo a ser menos irritables y agresivos.